# QUADAS CRITERIA FOR EVALUATING DIAGNOSTIC ACCURACY STUDIES

Table 2 The Quadas tool

Item | | Yes | No | Unclear
1. | Was the spectrum of patients representative of the patients who will receive the test in practice? | ( ) | ( ) | ( )
2. | Were selection criteria clearly described? | ( ) | ( ) | ( )
3. | Is the reference standard likely to correctly classify the target condition? | ( ) | ( ) | ( )
4. | Is the time period between reference standard and index test short enough to be reasonably sure that the target condition did not change between the two tests? | ( ) | ( ) | ( )
5. | Did the whole sample or a random selection of the sample, receive verification using a reference standard of diagnosis? | ( ) | ( ) | ( )
6. | Did patients receive the same reference standard regardless of the index test result? | ( ) | ( ) | ( )
7. | Was the reference standard independent of the index test (i.e. the index test did not form part of the reference standard)? | ( ) | ( ) | ( )
8. | Was the execution of the index test described in sufficient detail to permit replication of the test? | ( ) | ( ) | ( )
9. | Was the execution of the reference standard described in sufficient detail to permit its replication? | ( ) | ( ) | ( )
10. | Were the index test results interpreted without knowledge of the results of the reference standard? | ( ) | ( ) | ( )
11. | Were the reference standard results interpreted without knowledge of the results of the index test? | ( ) | ( ) | ( )
12. | Were the same clinical data available when test results were interpreted as would be available when the test is used in practice? | ( ) | ( ) | ( )
13. | Were uninterpretable/intermediate test results reported? | ( ) | ( ) | ( )
14. | Were withdrawals from the study explained? | ( ) | ( ) | ( )

Source: Whiting P, Rutjes AW, Reitsma JB, Bossuyt PM, Kleijnen J, Whiting P, et al. The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Medical Research Methodology 2003;3:25. Used with permission.