# SEARCH STRATEGY

Symbol | Concept | Search Strategy (PubMed)
D | Dementia | “dementia”[MeSH Terms] OR “dementia”[All Fields]
SS | Signs + Symptoms | (((((“signs + symptoms”[MeSH Terms] OR (“signs”[All Fields] + “symptoms”[All Fields]) OR “signs + symptoms”[All Fields]) OR (warning sign[All Fields] OR warning signal[All Fields] OR warning signal/precue[All Fields] OR warning signals[All Fields] OR warning signs[All Fields] OR warning signs/symptoms[All Fields])) OR (red flag[All Fields] OR red flagging[All Fields] OR red flags[All Fields])) OR presenting[All Fields]) OR (suspect[All Fields] OR suspected[All Fields])) OR (predict[All Fields] OR predictor[All Fields] OR predictors[All Fields])
CS | Cross-Sectional Studies | “Cross-Sectional Studies”[Mesh]
SR | Systematic Review Subset | systematic[sb]
G | Guidelines, Consensus Statement Publication Type | Guideline [pt] OR Consensus Development Conference [pt]
T | Specific Tests | ((“montreal cognitive assessment”[tiab]))) OR ((“moca”[tiab]))) OR ((“slums”[tiab]))) OR ((“st louis university mental status”[tiab]))) OR ((“saint louis university mental status”[tiab]))) OR ((“short test of mental status”[tiab]))) OR ((“STMS”[tiab]))) OR ((“General Practitioner Assessment of Cognition”[tiab]))) OR ((“GPCog”[tiab]))) OR ((“mini-cog”[tiab]))) OR ((“mini cog”[tiab]))) OR ((“orientation memory concentration”[tiab]))) OR ((“bomc”[tiab])))) NOT ((poverty areas[mesh]))

All searches were performed in July of 2009

Dementia Review #1 Key Question #1

PubMed

Primary Studies

(D + SS + CS) = 518

Secondary Studies (systematic reviews, guidelines or consensus statements only not general reviews)

((D + SS) + (SR OR G)) = 322

Additional databases

Cochrane central register of controlled trials and database of abstracts of reviews of effects

1 | dementia.mp.
2 | (signs and symptoms).mp
3 | warning sign.mp.
4 | warning signal.mp.
5 | red flag*.mp.
6 | presenting.mp.
7 | suspect.mp.
8 | suspected.mp.
9 | predict*.mp
10 | 8 or 6 or 4 or 3 or 7 or 9 or 2 or 5
11 | 1 and 10

229 results after de-duplication 201

CINAHL

S1 | (“dementia”) or (MH “Dementia+”)
S2 | (“signs and symptoms”) or (MH “Signs and Symptoms (Non-Cinahl)”)
S3 | “warning signs”
S4 | “warning signal”
S5 | “red flag*”
S6 | “presenting”
S7 | “suspect”
S8 | “suspected”
S9 | “predict”
S10 | predictor*
S11 | S2 or S3 or S4 or S5 or S6 or S7 or S8 or S9 or S10
S12 | (“dementia”) or (MM “Dementia+”)
S13 | S11 and S12
S14 | S11 and S12 Narrow by Subject: Major Heading 0:- Dementia

367 results after de-duplication 309

PsychINFO

1 | exp *Dementia/ | 30642
2 | (signs and symptoms).mp. [mp=title, abstract, heading word, table of contents, key concepts] | 5567
3 | warning sign.mp. or exp Warnings/ | 738
4 | red flag.mp. | 42
5 | red flags.mp. | 77
6 | exp Symptoms/or presenting.mp. | 131298
7 | suspect.mp. | 1854
8 | suspected.mp. | 4720
9 | predict.mp. | 36261
10 | predictor.mp. | 27521
11 | predictors.mp. | 38646
12 | 6 or 11 or 3 or 7 or 9 or 2 or 8 or 4 or 10 or 5 | 222250
13 | 1 and 12 | 4251
14 | limit 13 to (“0800 literature review” or “0830 systematic review” or 1200 meta analysis)

208 Results after de-duplication 192

AGELINE

Title: dementia

AND

Title: “signs and symptoms” ; “warning sign” ; “warning signal” ; “red flag” ; “red flags” ; presenting ; suspect ; suspected ; predict ; predictor

39 items after de-duplication 30 unique

We also re-executed the search described in Mitchell, 2008 in Medline.

(subjective memory OR memory complaint* OR memory difficult* [abstract])AND (Dementia OR Alzheimer* OR mild cognitive [abstract]) AND (validity OR diagnosis OR sensitivity OR specificity OR accuracy OR re receiveOperator OR ROC [full text]) limited to 2008-Sept 2009 (date of search)

79 Results

Dementia Review #1 Key Question #2 & 3

PubMed

(D + T) = 54

Additional databases (named tests were searched in the following databases)

Cochrane central register of controlled trials and database of abstracts of reviews of effects: 27

Results, after de-duplication 0

HAPI: 24 Results, after de-duplication 23

PsycINFO: 87 Results, after de-duplication 74

CINAHL: 48 Results, after de-duplication 44