# SUMMARY AND DISCUSSION

## SUMMARY OF EVIDENCE BY KEY QUESTION

### Key Question #1 What is the effectiveness of screening for delirium in adult inpatients? 1a. Do these results vary by medical unit, age, gender or comorbid conditions? 1b. Does screening for delirium improve clinical outcomes?

We identified no randomized controlled trials of screening for delirium in hospitalized patients. There is no direct evidence that screening for delirium is beneficial or harmful. However, universal screening may pose harms, such as misclassification, subsequent treatment of non-delirious patients or misdiagnosis of those with delirium. Opportunity costs include the time to administer screening tests and follow-up (including those of the consultants-typically a psychiatric consult) required for positive results. Additionally, we found no evidence from recent systematic reviews that pharmacologic and non-pharmacologic delirium treatments improve outcomes. Therefore, we conclude that the evidence is insufficient about the net benefit of delirium screening among all hospitalized patients or subgroups of patients as defined by age, gender, comorbidities or admission to intensive care units.

### Key Question #2 What are the effectiveness and harms of delirium prevention strategies in acute elderly inpatients? 2a. Do these results vary by medical unit, age, gender or comorbid conditions?

Low level evidence suggests that pharmacologic strategies using analgesia via fascia iliaca compartmental block, antipsychotics, and lighter anesthesia may be useful in delirium prevention. However, there were only a few studies, small in size, examining each category of prevention medications, and more research is needed. Pre-operative administration of statins was not found to effect the incidence of delirium. The evidence for peri-operative use of cholinesterase inhibitors and continuous epidural bupivicaine plus fentanyl versus continuous intravenous fentanyl is mixed.

The evidence shows that multi-component strategies were generally successful in delirium prevention, although these interventions varied widely and often involved multiple strategies and disciplines, making it difficult to determine which components of the multi-component strategies may be effective. The evidence suggests that staff education alone or music therapy may be effective strategies, although there are currently only two studies supporting these interventions. There is no evidence that bright light therapy is an effective strategy for delirium prevention.

The evidence suggests that there are few harms associated with the methods used in these studies for delirium prevention. None of the included studies were stratified by medical unit, age or comorbid conditions. Therefore, we are unable to ascertain whether effectiveness or harms varied by medical unit, age, gender or comorbid conditions.

### KEY QUESTION #3 What is the comparative diagnostic accuracy of the tools used to detect delirium 3a. In elderly medical and surgical inpatients? 3b. In elderly ICU inpatients?

A systematic review of bedside instruments concluded that the CAM was a suitable tool for medical and surgical inpatients, many of whom were evaluated in geriatric units. The ease of administration (completion in less than 5 minutes) was also considered although it was noted that administrators should be trained for optimal use and that the CAM was originally developed for use in conjunction with a formal cognitive assessment. The accuracy of bedside instruments delivered by individuals without training as stand-alone tools for delirium screening is not known. Fewer studies have evaluated the diagnostic accuracy of tools to detect delirium for elderly ICU inpatients. The CAM-ICU, a version of the CAM adapted for use in the ICU, appears to have high specificity but sensitivity varies (ranging from 64 to 100%) indicating that some patients with delirium will not be identified using the CAM-ICU alone. Not all of these studies were restricted to elderly patients and most excluded patients with neurological disease or cognitive dysfunction. Other tools have been evaluated in only one or two studies.

## RECOMMENDATIONS FOR FUTURE RESEARCH

The highest future research need is to conduct a randomized trial to evaluate the effectiveness and harms of screening for delirium in adults admitted to hospitals. Enrollment could target individuals likely to be at increased risk for, and thus hopefully at greatest benefit of, successful screening, prevention and treatment options. These could include individuals who are elderly, those with multiple comorbid conditions including mental health and cognitive impairment, and those receiving or likely to receive interventions or medications that can increase the risk of delirium and patients admitted to intensive care units. Additional work is needed to more clearly assess the harms associated with delirium screening and prevention, including the opportunity costs to health service personnel. These opportunity costs include the time and effort to administer screening tools as well as the downstream effects that occur based on follow-up of positive screen results or the efforts required for preventive strategies. More research is needed to verify the findings that some pharmacologic and nonpharmacologic strategies are helpful in the prevention of delirium, particularly in larger and more diverse populations, and with reports stratified by age, medical unit and comorbid conditions. Additionally, more research is needed to start to identify which components of the multi-component non-pharmacologic strategies may be most successful in delirium prevention. Investigations regarding delirium that may be provoked only by certain medication use (in the absence of other causes) would be very helpful; they may well have different prognoses than the multifactorial delirium. This research may offer some recommendations for prevention strategies that could easily be implemented. Finally, continued evaluation of diagnostic tools is warranted including the effects of training on diagnostic accuracy and the use of the tools in combination with other (e.g., cognitive) patient assessments.

## CONCLUSIONS

Our review of the evidence on screening for and prevention and diagnosis of delirium finds the following:

1. There is insufficient evidence regarding benefits and harms of delirium screening in hospitalized patients including subgroups of patients as defined by age, gender, comorbidities, or ICU admission. We identified no randomized trials of screening for delirium in hospitalized patients. Conducting large pragmatic delirium screening trials is a high-priority research need.
2. There are low quality data regarding pharmacological strategies to prevent delirium. Many proactive preventive strategies have not been examined; those that have are typically reported in only a single trial. In addition, sample sizes are typically small, populations represent only selected groups of patients, and there is little consistency or completeness of outcomes reporting.
3. Multi-component interventions hold promise and are widely used in real world settings but few randomized trials have been reported. The absolute effectiveness and the contributing effectiveness of individual components is not well known but most appear to include some method of staff education to increase awareness of signs/symptoms and encourage reporting of delirium with subsequent earlier intervention.
4. Available diagnostic tests have acceptable diagnostic operating characteristics in the populations and settings where they have been studied and when administered by individuals with adequate training. Concurrent mental status testing may also be a factor in accuracy of diagnosis with these tests. It is not known whether the operating characteristics are robust across a wide range of populations and settings where the prevalence and incidence of delirium varied from the reported studies.
5. Additional research is needed to evaluate the clinical effectiveness and harms of screening, pharmacological and non-pharmacological interventions to prevent delirium applied to a larger and more diverse population, and diagnostic tools used in a broader range of populations and settings.