# REFERENCES

1 Cole MG, Ciampi A, Belzile E, Zhong L. Persistent delirium in older hospital patients: a systematic review of frequency and prognosis. Age Ageing. 2009;38:19-26. [pmid: 19017678].
2 Witlox J, Eurelings LS, de Jonghe JF, Kalisvaart KJ, Eikelenboom P, van Gool WA. Delirium in elderly patients and the risk of postdischarge mortality, institutionalization, and dementia: a meta-analysis. JAMA. 2010;304:443-51. [pmid: 20664045].
3 Marcantonio ER. In the Clinic: Delirium. Ann Intern Med. 2011;154:ITC6-1. ITC6-16. [pmid: 21646553].
4 Rudolph JS, Marcantonaio ER. Postoperative delirium: acute change with long-term implications. Anesth Analg. 2011;112:1202-11. [pmid: 21474660].
5 Inouye SK, Foreman MD, Mion LC, Katz KH, Cooney LM. Nurses' recognition of delirum and its symptoms. Comparison of nurse and researcher ratings. Arch Intern Med. 2001;161:2467-73. [pmid: 11700159].
6 Inouye SK. Delirium in older persons. N Engl J Med. 2006;354:1157-65. [pmid: 16540616].
7 Delirium: diagnosis, prevention and management. Revision July 2010. Available at www.nice.org.uk/CG103. March 30, 2011.
8 Simel DL. Update: primer on precision and accuracy. Simel DL, Rennie D, editors. Rationale Clinical Examination: The Evidence-Based Clinical Diagnosis. New York, NY. McGraw-Hill. 2009:9-16.
9 Levkoff S, Cleary P, Liptzin B, Evans DA. Epidemiology of delirium: an overview of research issues and findings. Int Psychogeriatr. 1991;3:149-67. [pmid: 1811770].
10 Trzepacz PT. Delirium. Advances in diagnosis, pathophysiology, and treatment. Psychiatr Clin North Am. 1996;19:429-48. [pmid: 8856810].
11 Francis J, Martin D, Kapoor WN. A prospective study of delirium in hospitalized elderly. JAMA. 1990;263:1097-101. [pmid: 2299782].
12 Dautzenberg PLJ, Mulder LJ, Olde Rikkert MGM, Wouters CJ, Loonen AJM. Delirium in elderly hospitalised patients: protective effects of chronic rivastigmine usage. Int J Geriatr Psychiatry. 2004;19:641-4. [pmid: 15254920].
13 Williams-Russo P, Urquhart BL, Sharrock NE, Charlson ME. Post-operative delirium: predictors and prognosis in elderly orthopedic patients. J Am Geriatr Soc. 1992;40:759-67. [pmid: 1634718].
14 McCusker J, Cole M, Abrahamowicz M, Primeau F, Belzile E. Delirium predicts 12-month mortality. Arch Intern Med. 2002;162:457-63. [pmid: 11863480].
15 Inouye SK, Rushing JT, Foreman MD, Palmer RM, Pompei P. Does delirium contribute to poor hospital outcomes? A three-site epidemiologic study. J Gen Intern Med. 1998;13:234-42. [pmid: 9565386].
16 Stevens LE, de Moore GM, Simpson JM. Delirium in hospital: does it increase length of stay?. Aust N Z J Psychiatry. 1998;32:805-8. [pmid: 10084344].
17 Inouye SK. The dilemma of delirium: clinical and research controversies regarding diagnosis and evaluation of delirium in hospitalized elderly medical patients. Am J Med. 1994;97:278-88. [pmid: 8092177].
18 Lemiengre J, Nellis T, Joosten E, et al. Detection of delirium by bedside nurses using the confusion assessment method. J Am Geriatr Soc. 2006;54:685-9. [pmid: 16686883].
19 Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions. Version 5.0.2 [updated September 2009]. The Cochrane Collaboration. 2009. Available at www.cochrane-handbook.org. August 29, 2011.
20 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. 2010;63:513-23. [pmid: 19595577].
21 Siddiqi N, Stockdale R, Britton AM, Holmes J. Interventions for preventing delirium in hospitalised patients. Cochrane Database Syst Rev. 2007:CD005563.
22 O'Mahoney R, Murthy L, Akunne A, Young J. for the Guideline Development Group. Synopsis of the National Institute for Health and Clinical Excellence guideline for prevention of delirium. Ann Intern Med. 2011;154:746-51. [pmid: 21646557].
23 Diaz V, Rodriguez J, Barrientos P, et al. [Use of procholinergics in the prevention of postoperative delirium in hip fracture surgery in the elderly. A randomized controlled trial]. Rev Neurol. 2001;33:716-9. [pmid: 11784964].
24 Hennekens CH, Buring JE, Mayrent SL. Epidemiology in medicine. Chicago, IL. Lippincott Williams & Wilkins. 1987.
25 Clinical Practice Guidelines for the Management of Delirium in Older People. Revision October 2006. Available at www.health.vic.gov.au/acute-agedcare/delirium-cpg.pdf. March 30, 2011.
26 Siddiqi N, House AO, Holmes JD. Occurrence and outcome of delirium in medical in-patients: a systematic literature review. Age Ageing. 2006;35:350-64. [pmid: 16648149].
27 Lonergan E, Britton AM, Luxenberg J, Wyller T. Antipsychotics for delirium. Cochrane Database Syst Rev. 2007:CD005594.
28 Seitz DP, Gill SS, van Zyl LT. Antipsychotics in the treatment of delirium: a systematic review. J Clin Psychiatry. 2007;68:11-21. [pmid: 17284125].
29 Campbell N, Boustani MA, Ayub A, et al. Pharmacological management of delirium in hospitalized adults--a systematic evidence review. J Gen Intern Med. 2009;24:848-53. [pmid: 19424763].
30 Fong TG, Tulebaev SR, Inouye SK. Delirium in elderly adults: diagnosis, prevention and treatment. Nat Rev Neurol. 2009;5:210-20. [pmid: 19347026].
31 Young J, Murthy L, Westby M, Akunne A, O'Mahony R. Diagnosis, prevention, and management of delirium: summary of NICE guidance. BMJ. 2010;341:247-9.
32 Michaud L, Bula C, Berney A, et al. Delirium: guidelines for general hospitals. J Psychosom Res. 2007;62:371-83. [pmid: 17324689].
33 Guidelines for the prevention, diagnosis and management of delirium in older people in hospital. Revision January 2006. Available at http://www.bgs.org.uk/Publications/Clinical%20Guidelines/clinical_1-2_delirium.htm. March 30, 2011.
34 Jacobi J, Fraser GL, Coursin DB, et al. Clinical practice guidelines for the sustained use of sedatives and analgesics in the critically ill adult. Crit Care Med. 2002;30:119-41. [pmid: 11902253].
35 Wei LA, Fearing MA, Sternberg EJ, Inouye SK. The Confusion Assessment Method: a systematic review of current usage. J Am Geriatr Soc. 2008;56:823-30. [pmid: 18384586].
36 Delirium. Revision April 24, 2010: Available at http://www.mayoclinic.com/health/delirium/DS01064. August 11, 2011.
37 Al-Aama T, Brymer C, Gutmanis I, Woolmore-Goodwin SM, Esbaugh J, Dasgupta M. Melatonin decreases delirium in elderly patients: a randomized, placebo-controlled trial. Int J Geriatr Psychiatry. 2011;26:687-94. [pmid: 20845391].
38 Larsen KA, Kelly SE, Stern TA, et al. Administration of olanzapine to prevent postoperative delirium in elderly joint-replacement patients: A randomized, controlled trial. Psychosomatics. 2010;51:409-18. [pmid: 20833940].
39 Sieber FE, Zakriya KJ, Gottschalk A, et al. Sedation depth during spinal anesthesia and the development of postoperative delirium in elderly patients undergoing hip fracture repair. Mayo Clin Proc. 2010;85:18-26. [pmid: 20042557].
40 Gamberini M, Bolliger D, Lurati Buse GA, et al. Rivastigmine for the prevention of postoperative delirium in elderly patients undergoing elective cardiac surgery--a randomized controlled trial. Crit Care Med. 2009;37:1762-8. [pmid: 19325490].
41 Hudetz JA, Patterson KM, Iqbal Z, et al. Ketamine attenuates delirium after cardiac surgery with cardiopulmonary bypass. J Cardiothorac Vasc Anesth. 2009;23:651-7. [pmid: 19231245].
42 Maldonaldo JR, Wysong A, van der Staare PJA, Block T, Miller C, Reitz BA. Dexmedetomidine and the reduction of postoperative delirium after cardiac surgery. Psychosomatics. 2009;50:206-17. [pmid: 19567759].
43 Mouzopoulos G, Vasiliadis G, Lasanianos N, Nikolaras G, Morakis E, Kaminaris M. Fascia iliaca block prophylaxis for hip fracture patients at risk for delirium: a randomized placebo-controlled study. J Orthop Traumatol. 2009;10:127-33. [pmid: 19690943].
44 Prakanrattana U, Prapaitrakool S. Efficacy of risperidone for prevention of postoperative delirium in cardiac surgery. Anaesth Intensive Care. 2007;35:714-9. [pmid: 17933157].
45 Sampson EL, Raven PR, Ndhlovu PN, et al. A randomized, double-blind, placebo-controlled trial of donepezil hydrochloride (Aricept) for reducing the incidence of postoperative delirium after elective total hip replacement. Int J Geriatr Psychiatry. 2007;22:343-9. [pmid: 17006875].
46 Kalisvaart KJ, de Jonghe JF, Bogaards MJ, et al. Haloperidol prophylaxis for elderly hip-surgery patients at risk for delirium: a randomized placebo-controlled study. J Am Geriatr Soc. 2005;53:1658-66. [pmid: 16181163].
47 Liptzin B, Laki A, Garb JL, Fingeroth R, Krushell R. Donepezil in the prevention and treatment of post-surgical delirium. Am J Geriatr Psychiatry. 2005;13:1100-6. [pmid: 16319303].
48 Papaioannou A, Fraidakis O, Michaloudis D, Balalis C, Askitopoulou H. The impact of the type of anesthesia on cognitive status and delirium during the first postoperative days in elderly patients. Eur J Anaesthesiol. 2005;22:492-9. [pmid: 16045136].
49 Aizawa K, Kanai T, Saikawa Y, et al. A novel approach to the prevention of postoperative delirium in the elderly after gastrointestinal surgery. Surg Today. 2002;32:310-4. [pmid: 12027195].
50 Kaneko T, Cai J, Ishikura T, et al. Prophylactic consecutive administration of haloperidol can reduce the occurrence of postoperative delirium in gastrointestinal surgery. Yonago Acta Medica. 1999;42:179-84.
51 Berggren D, Gustafson Y, Eriksson B, et al. Postoperative confusion after anesthesia in elderly patients with femoral neck fractures. Anesth Analg. 1987;66:497-504. [pmid: 3578861].
52 Katznelson R, Djaiani GN, Borger MA, et al. Preoperative use of statins is associated with reduced early delirium rates after cardiac surgery. Anesthesiology. 2009;110:67-73. [pmid: 19104172].
53 Del Rosario E, Esteve N, Sernandez MJ, Batet C, Aguilar JL. Does femoral nerve analgesia impact the development of postoperative delirium in the elderly? A retrospective investigation. Acute Pain. 2008;10:59-64.
54 Savage GJ, Metzger JT. The prevention of postanesthetic delirium. Plast Reconstr Surg. 1978;62:81-4. [pmid: 662967].
55 Lundstrom M, Olofsson B, Stenvall M, et al. Postoperative delirium in old patients with femoral neck fracture: a randomized intervention study. Aging Clin Exp Res. 2007;19:178-86. [pmid: 17607084].
56 Taguchi T, Yano M, Kido Y. Influence of bright light therapy on postoperative patients: a pilot study. Intensive Crit Care Nurs. 2007;23:289-97. [pmid: 17692522].
57 McCaffrey R, Locsin R. The effect of music on pain and acute confusion in older adults undergoing hip and knee surgery. Holist Nurs Pract. 2006;20:218-26. [pmid: 16974175].
58 Lundstrom M, Edlund A, Karlsson S, Brunnstrom B, Bucht G, Gustafson Y. A multifactorial intervention program reduces the duration of delirium, length of hospitalization, and mortality in delirious patients. J Am Geriatr Soc. 2005;53:622-8. [pmid: 15817008].
59 Marcantonio ER, Flacker JM, Wright RJ, Resnick NM. Reducing delirium after hip fracture: a randomized trial. J Am Geriatr Soc. 2001;49:516-22. [pmid: 11380742].
60 Ushida T, Yokoyama T, Kishida Y, et al. Incidence and risk factors of postoperative delirium in cervical spine surgery. Spine. 2009;34:2500-4. [pmid: 19927098].
61 Vidan MT, Sanchez E, Alonso M, Montero B, Ortiz J, Serra J. An intervention integrated into daily clinical practice reduces the incidence of delirium during hospitalization in elderly patients. J Am Geriatr Soc. 2009;57:2029-36. [pmid: 19754498].
62 Kratz A. Use of the acute confusion protocol: a research utilization project. J Nurs Care Qual. 2008;23:331-7. [pmid: 18806646].
63 Robinson S, Rich C, Weitzel T, Vollmer C, Eden B. Delirium prevention for cognitive, sensory, and mobility impairments. Res Theory Nurs Pract. 2008;22:103-13. [pmid: 18578220].
64 Vollmer C, Rich C, Robinson S. How to prevent delirium: a practical protocol. Nursing. 2007;37:26-8. [pmid: 17882065].
65 Caplan GA, Harper EL. Recruitment of volunteers to improve vitality in the elderly: the REVIVE study. Intern Med J. 2007;37:95-100. [pmid: 17229251].
66 Harari D, Hopper A, Dhesi J, Babic-Illman G, Lockwood L, Martin F. Proactive care of older people undergoing surgery (‘POPS’): designing, embedding, evaluating and funding a comprehensive geriatric assessment service for older elective surgical patients. Age Ageing. 2007;36:190-6. [pmid: 17259638].
67 Naughton BJ, Saltzman S, Ramadan F, Chadha N, Priore R, Mylotte JM. A multifactorial intervention to reduce prevalence of delirium and shorten hospital length of stay. J Am Geriatr Soc. 2005;53:18-23. [pmid: 15667371].
68 Tabet N, Hudson S, Sweeney V, et al. An educational intervention can prevent delirium on acute medical wards. Age Ageing. 2005;34:152-6. [pmid: 15713859].
69 Wong DM, Niam T, Bruce JJ, Bruce DG. Quality project to prevent delirium after hip fracture. Australasian J Ageing. 2005;24:174-7.
70 Milisen K, Foreman MD, Abraham IL, et al. A nurse-led interdisciplinary intervention program for delirium in elderly hip-fracture patients. J Am Geriatr Soc. 2001;49:523-32. [pmid: 11380743].
71 Inouye SK, Bogardus ST Jr, Charpentier PA, et al. A multicomponent intervention to prevent delirium in hospitalized older patients. N Engl J Med. 1999;340:669-76. [pmid: 10053175].
72 Rizzo JA, Bogardus ST Jr, Leo-Summers L, Williams CS, Acampora D, Inouye SK. Multicomponent targeted intervention to prevent delirium in hospitalized older patients: what is the economic value?. Med Care. 2001;39:740-52. [pmid: 11458138].
73 Inouye SK, Bogardus ST Jr, Williams CS, Leo-Summers L, Agostini JV. The role of adherence on the effectiveness of nonpharmacologic interventions: evidence from the delirium prevention trial. Arch Intern Med. 2003;163:958-64. [pmid: 12719206].
74 Leslie DL, Zhang Y, Bogardus ST, Holford TR, Leo-Summers LS, Inouye SK. Consequences of preventing delirium in hospitalized older adults on nursing home costs. J Am Geriatr Soc. 2005;53:405-9. [pmid: 15743281].
75 Leslie DL, Zhang Y, Holford TR, Bogardus ST, Leo-Summers LS, Inouye SK. Premature death associated with delirium at 1-year follow-up. Arch Intern Med. 2005;165:1657-62. [pmid: 16043686].
76 Lundstrom M, Edlund A, Lundstrom G, Gustafson Y. Reorganization of nursing and medical care to reduce the incidence of postoperative delirium and improve rehabilitation outcome in elderly patients treated for femoral neck fractures. Scand J Caring Sci. 1999;13:193-200. [pmid: 12033125].
77 Wanich CK, Sullivan-Marx EM, Gottlieb GL, Johnson JC. Functional status outcomes of a nursing intervention in hospitalized elderly. Image J Nurs Sch. 1992;24(3):201-7. [pmid: 1521848].
78 Gustafson Y, Brännström B, Berggren D, et al. A geriatric-anesthesiologic program to reduce acute confusional states in elderly patients treated for femoral neck fractures. J Am Geriatric Soc. 1991;39:655-62.
79 Wong CL, Holroyd-Leduc J, Simel DL, Straus SE. Does this patient have delirium?: value of bedside instruments. JAMA. 2010;304:779-86. [pmid: 20716741].
80 White CM, Ip S, McPheeters M, et al. Using Existing Systematic Reviews To Replace De Novo Processes in Conducting Comparative Effectiveness Reviews, Methods Guide for Comparative Effectiveness Reviews. 2011/03/25 ed. Rockville, MD. Agency for Healthcare Research and Quality. 2008.
81 Shea BJ, Grimshaw JM, Wells GA, et al. Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC Med Res Methodol. 2007;7:10. [pmid: 17302989].
82 Farrell KR, Ganzini L. Misdiagnosing delirium as depression in medically ill elderly patients. Arch Intern Med. 1995;155:2459-64. [pmid: 7503605].
83 González M, de Pablo J, Fuente E, et al. Instrument for detection of delirium in general hospitals: adaptation of the confusion assessment method. Psychosomatics. 2004;45:426-31. [pmid: 15345788].
84 Inouye SK, van Dyck CH, Alessi CA, Balkin S, Siegal AP, Horwitz RI. Clarifying confusion: the confusion assessment method. A new method for detection of delirium. Ann Intern Med. 1990;113:941-8. [pmid: 2240918].
85 Laurila JV, Pitkala KH, Strandberg TE, Tilvis RS. Confusion Assessment Method in the diagnostics of delirium among aged hospital patients: Would it serve better in screening than as a diagnostic instrument?. Int J Geriatr Psychiatry. 2002;17:1112-9. [pmid: 12461759].
86 Leung JM, Leung VW, Leung CM, Pan PC. Clinical utility and validation of two instruments (the Confusion Assessment Method algorithm and the Chinese version of Nursing Delirium Screening Scale) to detect delirium in geriatric inpatients. Gen Hosp Psychiatry. 2008;30:171-6. [pmid: 18291299].
87 Pompei P, Foreman M, Cassel C, Alessi C, Cox D. Detecting delirium among hospitalized older patients. Arch Intern Med. 1995;155:301-7. [pmid: 7832602].
88 Zou Y, Cole MJ, Rimeau FJ, McCusker J, Bellavance F, Laplante J. Detection and diagnosis of delirium in the elderly: psychiatrist diagnosis, Confusion Assessment Method, or consensus diagnosis?. Int Psychogeriatr. 1998;10:303-8. [pmid: 9785149].
89 Gemert van LA, Schuurmans MJ. The Neecham Confusion Scale and the Delirium Observation Screening Scale: Capacity to discriminate and ease of use in clinical practice. BMC Nursing. 2007;6:3. [pmid: 17394635].
90 Schuurmans MJ, Shortridge-Bagget LM, Duursma SA. The Delirium Observation Screening Scale: a screening instrument for delirium. Res Theory Nurs Pract. 2003;17:31-50. [pmid: 12751884].
91 Rockwood K, Goodman J, Flynn M, Stolee P. Cross-validation of the Delirium Rating Scale in older patients. J Am Geriatr Soc. 1996;44:839-42. [pmid: 8675936].
92 Rosen J, Sweet RA, Mulsant BH, Rifai AH, Pasternak R, Zubenko GS. The Delirium Rating Scale in a psychogeriatric inpatient setting. J Neuropsychiatry Clin Neurosci. 1994;6:30-5. [pmid: 8148634].
93 Trzepacz PT, Brenner RP, Coffman G, van Thiel DH. Delirium in liver transplantation candidates. Biol Psychiatry. 1988;24:3-14. [pmid: 3285901].
94 de Rooij SE, van Munster BC, Korevaar JC, et al. Delirium subtype identification and the validation of the Delirium Rating Scale-Revised-98 (Dutch version) in hospitalized elderly patients. Int J Geriatr Psychiatry. 2006;21:876-82. [pmid: 16955454].
95 Matsouka Y, Miyake Y, Arakaki H, Tanaka K, Saeki T, Yamawaki S. Clinical utility and validation of the Japanese version of Memorial Delirium Assessment Scale in a psychogeriatric inpatient setting. Gen Hosp Psychiatry. 2001;23:36-40. [pmid: 11226556].
96 O'Keeffe ST, Gosney MA. Assessing attentiveness in older hospital patients: global assessment versus tests of attention. J Am Geriatr Soc. 1997;45:470-3. [pmid: 9100717].
97 Grassi L, Caraceni A, Beltrami E, et al. Assessing delirium in cancer patients. The Italian versions of the Delirium Rating Scale and the Memorial Delirium Assessment Scale. J Pain Symptom Manage. 2001;21:59-68. [pmid: 11223315].
98 Hestermann U, Bakenstrass M, Gekle I, et al. Validation of a German version of the Confusion Assessment Method for delirium detection in a sample of acute geriatric patients with a high prevalence of dementia. Psychopathology. 2009;42:270-6. [pmid: 19521144].
99 Rolfson DB, McElhaney JE, Jhangri GS, Rockwood K. Validity of the confusion assessment method in detecting postoperative delirium in the elderly. Int Psychogeriatr. 1999;11:431-8. [pmid: 10631588].
100 Ryan K, Leonard M, Guerin S, Donnelly S, Conroy M, Meagher D. Validation of the Confusion Assessment Method in the palliative care setting. Palliat Med. 2009;23:40-5. [pmid: 19010967].
101 Breitbart W, Rosenfeld B, Roth A, Smith MJ, Cohen K, Passik S. The Memorial Delirium Assessment Scale. J Pain Symptom Manage. 1997;13:128-37. [pmid: 9114631].
102 Gaudreau JD, Gagnosn P, Harel F, Roy MA. Impact on delirium detection of using a sensitive instrument integrated into clinical practice. Gen Hosp Psychiatry. 2005;27:194-9. [pmid: 15882766].
103 Andrew MK, Bhat R, Clark B, Freter SH, Rockwood MRH, Rockwood K. Inter-rater reliability of the DRS-R-98 in detecting delirium in frail elderly patients. Age Ageing. 2009;28(2):241-4. [pmid: 19179670].
104 de Negreiros DP, da Silva Meleiro AMA, Furlanetto LM, Trzepacz PT. Portuguese version of the Delirium Rating Scale-Revised-98: reliability and validity. Int J Geriatr Psychiatry. 2008;23:472-7. [pmid: 17922493].
105 Huang MC, Lee CH, Lai YC, Kao YF, Lin HY, Chen CH. Chinese version of the Delirium Rating Scale-Revised-98: reliability and validity. Compr Psychiatry. 2009;50:81-5. [pmid: 19059519].
106 Kazmierski J, Kowman M, Banach M, et al. Clinical utility and use of DSM-IV and ICD-10 criteria and the Memorial Delirium Assessment Scale in establishing a diagnosis of delirium after cardiac surgery. Psychosomatics. 2008;49:73-6. [pmid: 18212180].
107 Radtke FM, Franck M, Schust S, et al. A comparison of three scores to screen for delirium on the surgical ward. World J Surg. 2010;34:487-94. [pmid: 20066416].
108 Bruno JJ, Warren ML. Intensive care unit delirium. Crit Care Nurs Clin North Am. 2010;22:161-78. [pmid: 20541065].
109 Hart RP, Levenson JL, Sessler CN, Best AM, Schwartz SM, Rutherford LE. Validation of a cognitive test for delirium in medical ICU patients. Psychosomatics. 1996;37:533-46. [pmid: 8942204].
110 Ely EW, Margolin R, Francis J, et al. Evaluation of delirium in critically ill patients: validation of the Confusion Assessment Method for the Intensive Care Unit (CAM-ICU). Crit Care Med. 2001;29:1370-9. [pmid: 11445689].
111 Pisani MA, Araujo KLB, Van Ness PH, Zhang Y, Ely EW, Inouye SK. A research algorithm to improve detection of delirium in the intensive care unit. Crit Care. 2006;10:R121. [pmid: 16919169].
112 Luetz A, Heymann A, Radtke FM, et al. Different assessment tools for intensive care unit delirium: which score to use?. Crit Care Med. 2010;38:409-18. [pmid: 20029345].
113 Lin SM, Liu CY, Wang CH, et al. The impact of delirium on the survival of mechanically ventilated patients. Crit Care Med. 2004;32:2254-9. [pmid: 15640638].
114 Bergeron N, Dubois MJ, Dumont M, Dial S, Skrobik Y. Intensive Care Delirium Screening Checklist: evaluation of a new screening tool. Intensive Care Med. 2001;27:859-64. [pmid: 11430542].
115 McNicoll L, Pisani MA, Ely EW, Gifford D, Inouye SK. Detection of delirium in the intensive care unit: comparison of confusion assessment method for the intensive care unit with confusion assessment method ratings. J Am Geriatr Soc. 2005;53:495-500. [pmid: 15743296].
116 Ely EW, Inouye SK, Bernard GR, et al. Delirium in mechanically ventilated patients: validity and reliability of the confusion assessment method for the intensive care unit (CAM-ICU). JAMA. 2001;286:2703-10. [pmid: 11730446].
117 Plaschke K, von Haken R, Scholz M, et al. Comparison of the confusion assessment method for the intensive care unit (CAM-ICU) with the Intensive Care Delirium Screening Checklist (ICDSC) for delirium in critical care patients gives high agreement rate(s). Intensive Care Med. 2008;34:431-6. [pmid: 17994221].
118 Shyamsundar G, Raghuthaman G, Rajkumar AP, Jacob KS. Validation of memorial delirium assessment scale. J Crit Care. 2009;24:530-4. [pmid: 19327962].
119 Koolhoven I, Tjon-A-Tsien MR, van der Mast RC. Early diagnosis of delirium after cardiac surgery. Gen Hosp Psychiatry. 1996;18:448-51. [pmid: 8937914].
120 Van Rompaey B, Schuurmans MJ, Shortridge-Baggett LM, Truijen S, Elseviers M, Bossaert L. A comparison of the CAM-ICU and the NEECHAM Confusion Scale in intensive care delirium assessment: an observational study in non-intubated patients. Crit Care. 2008;12:R16. [pmid: 18282269].
121 Spronk PE, Riekerk B, Hofhuis J, Rommes JH. Occurrence of delirium is severely underestimated in the ICU during daily care. Intensive Care Med. 2009;35:1276-80. [pmid: 19350214].
122 van Eijk MMJ, van Marum RJ, Klijn IAM, de Wit N, Kesecioglu J, Slooter AJC. Comparison of delirium assessment tools in a mixed intensive care unit. Crit Care Med. 2009;37:1881-5. [pmid: 19384206].
123 Guenther U, Popp J, Koecher L, et al. Validity and reliability of the CAM-ICU Flowsheet to diagnose delirium in surgical ICU patients. J Crit Care. 2010;25:144-51. [pmid: 19828283].