# METHODS

## TOPIC DEVELOPMENT

This project was nominated by Nancy Schmid, ADPNS, a Nurse Executive at Syracuse VA Medical Center, with input from a technical expert panel of clinicians, researchers, and administrators.

The final key questions are:

1. What is the effectiveness of screening for delirium in adult inpatients?
  a. Do these results vary by medical unit, age, gender or comorbid conditions?
  b. Does screening for delirium improve clinical outcomes?
2. What are the effectiveness and harms of delirium prevention strategies in acute elderly inpatients?
  a. Do these results vary by medical unit, age, gender or comorbid conditions?
3. What is the comparative diagnostic accuracy of the tools used to detect delirium:
  a. In elderly medical and surgical inpatients?
  b. In elderly medical or surgical intensive care unit (ICU) inpatients?

An analytic framework (Figure 1) was developed to depict the potential pathway of a hospitalized adult patient. This report will focus on the outcomes and harms associated with screening (Key Question #1), preventive interventions (Key Questions #2), and diagnosis (Key Question #3).

Figure 1 Analytic Framework

## SEARCH STRATEGY

We searched MEDLINE, CINAHL, and PsycINFO from 1950 to November 2010 using standard search terms (Appendix A). We limited the search to peer-reviewed articles involving human subjects and published in the English language. Additional citations were identified from reference lists and Technical Expert Panel members.

## STUDY SELECTION

Physicians, nurses, and research assistants trained in the critical analysis of literature assessed for relevance the abstracts of citations identified from literature searches. Full-text articles of potentially relevant abstracts were retrieved for further review. A Study Selection Form (Appendix B) was used to guide this review.

Specific exclusion criteria for the screening and diagnosis questions were as follows:

1. Non-English publication
2. Population <16 yrs old
3. Alcohol-related delirium
4. Not hospitalized patients (nursing home or similar was excluded)
5. No reference standard (DSM III, III-R, or IV)
6. Index test and reference standard performed by same individual
7. Case series (<10 patients), case report, editorial, letter
8. Not patients with delirium
9. No outcomes of interest
10. Not a screening or diagnosis study

Specific exclusion criteria for the prevention question were as follows:

1. Non-English publication
2. Population <16 years old
3. Nursing home residents (or mixed hospital/nursing home if unable to get results of hospital only)
4. Case series, case report, editorial, letter
5. Not about delirium prevention

## DATA ABSTRACTION

Study characteristics, patient characteristics, and outcomes were extracted and evidence and outcomes tables, organized by key question, were created under the supervision of the Principal Investigator, a geriatric psychiatrist.

## QUALITY ASSESSMENT

We assessed study quality of randomized trials of prevention strategies (Key Question 2) according to the following criteria: 1) adequate allocation concealment, 2) blinding of key study personnel, 3) analysis by intention-to-treat, and 4) reporting of number of withdrawals/dropouts by group assignment.19 Studies were rated as good, fair, or poor quality. A rating of good generally indicated that the trial reported adequate allocation concealment, blinding, analysis by intent-to-treat, and reasons for dropouts/attrition were reported. Studies were generally rated poor if the method of allocation concealment was inadequate or not defined, blinding was not defined, analysis by intent-to-treat was not utilized, and reasons for dropouts/attrition were not reported and/or there was a high rate of attrition.

Study quality of studies reported for Key Question 3 (studies of diagnostic accuracy) was assessed using the method described in the Rationale Clinical Examination series.8 Briefly, studies are designated as Level of Evidence 1 if they present an independent, blinded comparison with a criterion standard in a large number (defined as 100 or more patients in the delirium diagnosis review) of consecutive individuals suspected of having the target condition or a Level of Evidence 2 if they meet all the criteria for Level 1 but enroll fewer than 100 patients. Level of Evidence 3 studies are similar to Level 1 or Level 2 studies but do not enroll patients consecutively. Studies with a non-independent comparison with the criterion standard and that enroll (at least in part) patients who obviously have the target condition are designated as Level of Evidence 4. Studies with a reference test of questionable validity are designated Level of Evidence 5.

## DATA SYNTHESIS

We constructed evidence tables showing the study characteristics and results for all included studies, organized by key question. We critically analyzed studies to compare their characteristics, methods, and findings. Pooled analyses were performed, where feasible, for studies of prevention strategies. All other data were narratively summarized.

## RATING THE BODY OF EVIDENCE

We assessed the overall quality of evidence for randomized trials of prevention strategies (Key Question #2) using the method reported by Owens et al.20 Briefly, for each outcome evaluated, the strength of the evidence was assessed based on: (1) risk of bias; (2) consistency; (3) directness; and (4) precision. Based on these four domains, the overall evidence was rated as: (1) high, meaning high confidence that the evidence reflects the true effect; (2) moderate, indicating moderate confidence that further research may change our confidence in the estimate of effect and may change the estimate; (3) low, meaning there is low confidence that the evidence reflects the true effect; and (4) insufficient, indicating that evidence either is unavailable or does not permit a conclusion. Due to heterogeneity in the interventions evaluated, we did not rate the overall strength of evidence for the non-randomized trials.

## PEER REVIEW

A draft version of this report was reviewed by technical experts and VA clinical leadership. Their comments and our responses are presented in Appendix C.