# SEARCH STRATEGIES

## Delirium screening and diagnosis

Database: Ovid MEDLINE(R)

Search Strategy:

--------------------------------------------------------------------------------

1. confusion.mp. or exp Confusion/
2. exp Delirium/ or delirium.mp.
3. deliri$.tw.
4. (NEECHAM or “Neelon and Champagne Confusion Scale”).tw.
5. (MMSE or mini-mental stat$ exam$).tw.
6. or/1-5
7. sensitiv$.mp.
8. predictive value$.mp.
9. accurac$.tw.
10. or/7-9
11. 6 and 10
12. limit 11 to english language
13. mass screening.mp. or exp Mass Screening/
14. diagnosis.mp. or exp Diagnosis/
15. 13 or 14
16. 12 and 15

## Delirium prevention

Database: Ovid MEDLINE(R) <1950 to November Week 2 2010>

Search Strategy:

--------------------------------------------------------------------------------

1. exp Delirium/
2. deliri*.mp.
3. exp Confusion/ or acute confusion.mp.
4. acute organic psychosyndrome.mp.
5. acute brain syndrome.mp.
6. metabolic encephalopathy.mp.
7. acute psycho-organic syndrome.mp.
8. clouded state.mp.
9. clouding of consciousness.mp.
10. exogenous psychosis.mp.
11. toxic psychosis.mp.
12. toxic confusion.mp.
13. or/1-12
14. exp Primary Prevention/
15. prevent*.mp.
16. avoid*.mp.
17. or/14-16
18. 13 and 17
19. exp Alcohol Withdrawal Delirium/
20. delirium tremens.ti.
21. 19 or 20
22. 18 not 21
23. exp animals/ not humans.sh.
24. 22 not 23
25. limit 24 to english language
26. limit 25 to yr=”1966 -Current”