# SUMMARY AND DISCUSSION

## KEY FINDINGS AND STRENGTH OF EVIDENCE

### Key Findings and Strength of Evidence

- Hospital- or population-based studies have reported that the risk of aspiration serious enough to require hospitalization during colonoscopy is very low (1 in 1000 or less). However, these studies have not documented NPO status and it is possible that the low rates are driven by more individuals having longer rather than shorter NPO status.
- In 3 RCTs and 2 observational studies (total n=2,318) comparing shorter NPO status to NPO status of at least 8 hours, no aspiration events were reported. Bowel preparation was completed at least 2 hours prior to colonoscopy in 2 studies and at least 3 hours prior to colonoscopy in one study. Another study allowed clear liquids up to 3 hours prior to colonoscopy and the remaining study only reported that bowel preparation was completed in the morning for an afternoon colonoscopy.
- One small RCT (n=113) reported a significantly lower percentage of rescheduled colonoscopies in the split-dose group compared to 2 groups that completed preparation the evening before the colonoscopy, although different preparation agents were used in the 3 groups. No studies reported on other resource use outcomes including unused procedure slots or increased volume of procedures by NPO status.
- Few studies assessing NPO status specified adverse events associated with colonoscopy as an outcome of interest and therefore adverse events may be underreported.
- Time from completion of colonic preparation to colonoscopy of 1 to 6 hours is associated with greater bowel preparation quality than time intervals of greater than 8 hours. Of 24 studies comparing split-dose versus non-split-dose preparation, 20 reported higher quality of bowel preparation with split-dose.
- Completion rate was not significantly different between NPO status groups in 5 RCTs; one large observational study reported a greater completion rate with shorter NPO status. Results were mixed for diagnostic yield and adenoma detection rate with no consistent findings based on NPO status. One study reported no documented complications of bowel perforation; no study reported on false negative colonoscopy.
- Among studies reporting adherence to the bowel preparation regimen, time lost from work, or sleep disruption, results were mixed with no clear benefit of split-dose regimens over same day regimens.
- Studies of NPO status typically excluded patients with serious comorbidities.
- For our co-primary outcomes, strength of evidence was low for aspiration and insufficient for rescheduled colonoscopies. For secondary outcomes, strength of evidence was moderate for completion rate based on pooled results from 5 RCTs, low for adenoma detection rate based on pooled results from 3 observational studies, and insufficient for diagnostic yield, bowel perforation, and false-negative colonoscopy (Appendix D).

## DISCUSSION

Colonoscopy is now the most frequently performed procedure in the US.57 The indications for colonoscopy include diagnostic evaluation of symptoms, screening, and surveillance. The goals of a successful colonoscopy program are safe and high-quality colonoscopic exams. Challenges to these goals include limited colonoscopy capacity, complexity of patient scheduling, and adequate bowel cleansing to ensure a high-quality exam. Quality of bowel preparation may be improved by administering the purgative agent closer to the time of colonoscopy, a practice widely adopted by the gastroenterology community in the form of split-dose preparation. However, optimizing bowel preparation quality needs to be balanced against potential increased risk of adverse events related to shorter duration of NPO status prior to colonoscopy.

This systematic review was conducted to review the evidence on the relationship between timing of NPO and the incidence of aspiration and colonoscopy rescheduling. Other outcomes included other anesthesia-related harms, bowel preparation quality, colonoscopy quality measures, resource use, and patient satisfaction.

### NPO Status and Aspiration Requiring Hospitalization

The most important potential risk of a shorter NPO duration is aspiration requiring hospitalization. The overall reported risk of aspiration events serious enough to require hospitalization during colonoscopy is extremely low. A population-based study in the US reported that between 0.1% and 0.14% of adults age 66 and older (mean = 75 years) had an aspiration requiring hospitalization during colonoscopy. Aspiration requiring hospitalization reported in adults of younger age was much lower. Although aspiration risk appears to be related to deep sedation, it is unknown if other factors, such as patient comorbidities, may be confounding that relationship. We found 5 studies (n=2,318) reporting no episodes of aspiration or sedation-related complications with NPO durations as low as 2 to 4 hours. One additional RCT (n=125) reported a single aspiration event but NPO status was 4 hours or less in both study groups. The “tolerable” rate of aspiration threshold for individuals undergoing an elective procedure that could potentially be modified by NPO status is not known. However, as with all procedures, adverse events will not be zero and the reported percents of aspirations requiring hospitalization events are of similar magnitude to other commonly accepted adverse effects of similar severity encountered in other procedures. Although the studies enrolled a total of 2,443 patients, the numbers may be still too small to assess for a rare outcome such as aspiration. We found 7 studies assessing other harms related to colonoscopy but none of the harms were related to timing of NPO prior to colonoscopy.

Gastric volume and acidity are regarded as markers of potential aspiration risk and severity. We found 2 studies that showed no difference in gastric volume with shorter (less than 2 hours before colonoscopy) versus overnight duration of NPO status prior to colonoscopy.14,31 Other studies of NPO status and gastric volume/pH before endoscopy or surgery also reported no differences. A 1996 study measured volume and pH of gastric aspirate in 88 patients undergoing endoscopy.58 Patients were randomly assigned to an overnight fast (both food and fluids) or consumption of 330 ml water at 7:30 am on the day of the procedure (with no food after midnight). The mean time from the fluid intake until endoscopy was 117 minutes. There was no significant difference between the 2 study groups in gastric volume (12.5 ml in the fluid intake group, 10.0 ml in the fasting group) or pH (2.0 in both groups). A subsequent study found no difference in gastric volume or pH between groups of patients assigned to drink 200 ml of water or full fat milk 90 minutes before endoscopy.59 Similarly, a study of 126 patients scheduled for elective surgery with general anesthesia found no difference in gastric fluid volume or pH between groups of patients who drank 300 mL of clear liquid of their choice 2 hours before the procedure and those who continued to fast after midnight.60 These results suggest that gastric volume and acidity do not differ whether water or other liquids are consumed 2 hours prior to a procedure compared to longer NPO durations.

It is important to note that not all aspirations are clinically significant pulmonary aspirations and many authors may include passive regurgitation. Warner et al61 outlined the diagnostic criteria for pulmonary aspirations as follows: 1) the presence of bilious secretions or particulate matter within the tracheo-bronchial tree by direct suctioning or by fiberoptic bronchoscopy, or 2) after the episode of passive regurgitation, postoperative chest radiograph demonstrated a new infiltrate that did not exist in the preoperative chest radiograph or on physical examination and that developed postoperatively within 24 hours. Using these criteria, a large population-based study reported a 4 year retrospective analysis (2001-2004) of perioperative pulmonary aspiration events.62 Of 99,441 surgical cases in adults performed with anesthesia, 14 had aspiration events for a rate of 1 in 7,103 or 0.014%. Ten of the 14 cases (70%) were the result of improper anesthesia technique. This suggests that the true risk of pulmonary aspiration may be lower than 1 in 1000. Studies of a US Medicare population,54 outpatients from 3 hospitals in Australia,55and a single hospital in Italy56 provide supporting evidence. For aspiration events serious enough to require hospitalization, the risk may be as low as 0.01%. These risks need to be weighed against the benefit of shorter NPO.

The concern shared by anesthesia providers is the risk of aspiration due to short duration between administration of purgative and the procedure. This concern is addressed by the American Society of Anesthesiology (ASA) guideline that recommends 2 hours of NPO prior to moderate sedation.10 Adherence to this guideline would permit use of split-dose regimens and reduce procedure cancellations due to patient oral ingestion at intervals greater than 2 hours prior to a procedure. However, based on responses from 55 VA chiefs of anesthesiology in March 2014, anesthesiologists across VHA appear to have differing policies and practices regarding NPO for elective procedures. For example 38% stated they require NPO after midnight, 15% require NPO for 6 hours, 11% require NPO for 6 hours for food and 4 hours for clear liquids (including 1 liter of bowel preparation solution), 32% require NPO for 6 hours for food and 2 hours for clear liquids (including 1 liter of bowel preparation solution), 2% require NPO for 6 hours for food and one hour for clear liquids (including 1 liter of bowel preparation solution), and 4% don't have a rule for NPO status for gastrointestinal procedures.(Personal Communication, Art Wallace, March 2014)

Possible reasons for not adhering to the ASA guidelines are concerns that laxatives may not be treated similar to ingestion of clear liquids and that the volume of laxative may be larger than that of other clear liquids. Studies that evaluated ingestion of clear liquids up to 2 hours prior to anesthesia administration suggest that this ingestion does not affect stomach volume or pH compared to earlier ingestion.14,31,58-60 Other reasons for non-adherence of anesthesia providers to the ASA guidelines need to be explored.

### NPO Status and Adequacy of Bowel Cleansing

For an effective and safe colonoscopy program, the adequacy of bowel cleansing is paramount. We found 39 studies (n=22,629) that reported the association of duration of NPO and quality of preparation comparing shorter (1 to 6 hours) versus longer duration (8 to 12 hours) between bowel preparation and colonoscopy. Thirty-one reported higher quality of bowel preparation with a shorter interval between preparation and colonoscopy and 8 reported no significant difference.

We were most interested in studies that reported NPO of < 4 hours compared to longer durations of NPO, as this is likely the most commonly used duration of NPO with the newer split-dose bowel preparations. We found 23 studies (RCTs or observational) that compared or included duration of NPO of < 4 hours to longer durations (usually > 8 hours). Nineteen reported a higher quality preparation with shorter duration (< 4) of NPO, 3 showed no difference, and 1 did not report on prep quality.

Multiple gastroenterology societies in the US and Europe have established guidelines in response to the recognized importance of adequate bowel preparation quality. The US Multi-Society Task Force on Colorectal Cancer, the European Society of Gastrointestinal Endoscopy and others5,7,63 now recommend using split-dose regimens for bowel preparation, such that the second dose of laxative is administered 4 to 6 hours before the colonoscopy with completion at least 2 hours before the exam.

Inadequate bowel preparation has multiple adverse consequences, both direct and downstream, that can broadly be categorized as the following:

1. Efficacy: Inadequate bowel preparation is associated with lower adenoma detection rates and lower cecal intubation rates which are risk factors for missed lesions, thus reducing the effectiveness of colonoscopy.64,65
2. Safety: Inadequate bowel preparation is associated with increased risk of electrocautery, longer procedure time, and reduced patient comfort, which can reduce the safety of colonoscopy.66
3. Capacity: Demand for colonoscopy is high given both screening and diagnostic indications, and the current capacity is inadequate to meet this demand. The VHA devotes a large amount of resources to improve the colonoscopic capacity and many VA facilities rely heavily on fee-basis and non-VA care to meet the colonoscopic capacity. Hence, maximizing capacity is of key importance in the VHA. Inadequate bowel preparation may reduce the colonoscopic capacity through cancelled procedures and resources required for rescheduling. Additionally, this may lead to poor patient satisfaction and delays in care. One study reported that for every 1% increase in inadequate bowel preparation, the cost of colonoscopy delivery increased by 1%.3
4. Effectiveness: Inadequate bowel preparation impairs a thorough inspection of the colonic mucosa and results in incomplete exams. Patients with incomplete exams may never reschedule, or at the very least, have delayed diagnostic evaluation due to rescheduling. Delays in diagnostic or screening exams may reduce the effectiveness of a colonoscopy program. The current VHA directive requires a colonoscopy within 60 days of a positive FOBT. Inadequate bowel preparation resulting in rescheduling colonoscopy may contribute to delays in colonoscopy. Unsatisfactory quality of cleansing also results in physicians recommending a repeat colonoscopy exam at a shorter interval compared to intervals recommended by multi-society guidelines. In one study, bowel preparations of fair quality were associated with more aggressive follow-up intervals in 60% of average risk asymptomatic individuals undergoing screening colonoscopy.67

Furthermore, quality of bowel preparation, adenoma detection rate, and cecal intubation rate are proposed quality measures for colonoscopy programs, at the facility and individual level. These have been adopted by the Centers for Medicare & Medicaid Services (CMS) as metrics in the physician quality reporting system (PQRS), associated with financial incentives, and starting in 2015, financial penalties to eligible practices.68

There are multiple bowel preparation agents available in the US, all with a single goal of achieving high quality of colon cleansing. Recent studies have focused on the different regimens of administration of the purgative and clearly demonstrate that, for better cleansing, splitting the dose, in which the laxative is split into two doses taken the day before and the day of colonoscopy, is superior to administering the entire laxative the night before the colonoscopy. 4 A recent meta-analysis of 29 studies comparing split-dose regimens to night-before regimens reported a rate difference of 22% (95%CI 16%, 27%) in achieving better cleansing with split-dose prep. 69 The study also found that the time interval between last administration of laxative and colonoscopy was the main factor driving the effect. The risk difference between split and non-split preparation was maintained when colonoscopy was performed within 3 hours from the end of laxative intake, but decreased after 4 to 5 hours (risk difference 18%), and was not statistically significant when the time interval was >5 hours. The authors also found higher compliance with the split-dose regimen (risk difference 9.4%; 95%CI 0.06, 0.13) regardless of type of laxative.

### NPO Status and Other Outcomes

We also examined the effect of variable timing of NPO on resource use, such as no-shows, cancellation, rescheduling, and other missed opportunities. Hypothetically, a shorter duration of NPO could improve capacity, if it reduced cancellations or aborted procedures due to poor preparation. On the contrary, a shorter duration of prep could be more difficult to adhere to, or to tolerate, resulting in missed appointments that would need to be rescheduled. We found one study (insufficient evidence) that reported fewer rescheduled colonoscopies in the shorter NPO status group and no studies reporting on other resource use outcomes.

Eleven studies reported on adherence to preparation or colonoscopy. Of these, 2 reported significantly higher adherence to preparation regimens with NPO of ≥ 1.5 hours versus > 8 hours and NPO of < 3 hours versus > 8 hours respectively. 13,21 The other 9 studies reported no difference in adherence to colonoscopy or to the preparation with variable duration of NPO. Patient satisfaction and willingness to repeat the preparation was higher with shorter duration of NPO, while less sleep loss was reported in 2 studies with NPO durations of ≥ 5 hours versus > 8 hours and ≥ 3 hours versus > 8 hours respectively. Of note, most studies had broad time ranges for duration of NPO status, and we were unable to derive a mean or median estimate.

### Summary of Evidence

In summary, we found low-strength evidence that procedure-related harms, such as risk of aspiration or other anesthesia-related harms from colonoscopy are not related to duration of NPO status prior to colonoscopy (Appendix D). Aspiration requiring hospitalizations among individuals undergoing colonoscopy is very low (1 in 1000 or less) and consistent in magnitude with complications of similar severity occurring during elective procedures. It is important to acknowledge that in the US there are no systematic tracking methods to track complications from colonoscopy, especially related to NPO status, and there is the possibility of under- or misreporting. We found evidence that shorter duration of NPO status prior to colonoscopy (< 4 hours) is associated with higher-quality bowel cleansing compared to longer duration of NPO prior to colonoscopy (> 8 hours). We found moderate strength evidence that shorter duration of NPO is not associated with higher rates of completion, and insufficient or low-strength evidence that shorter duration of NPO affects adenoma detection rates, diagnostic yield, or false negative colonoscopy (Appendix D). While there are many studies evaluating the association of bowel preparation quality and colonoscopy yield and quality indicators, there is limited evidence showing the direct relationship between duration of NPO and these outcomes. Only one study reported the effect of NPO status prior to colonoscopy on resource use. Results were mixed for patient adherence and patient satisfaction.

## LIMITATIONS AND APPLICABILITY

Our findings are limited by the relative paucity of information directly addressing the key questions. None of the studies were directly designed to address the key questions. Instead we used studies that primarily evaluated the effect of different regimens on bowel preparation to assess the effect of varying NPO status on the outcomes of interest for this report. Except for bowel preparation quality, few studies reported our outcomes of interest. In fact, only 5 studies reported on aspiration according to NPO status and one reported on rescheduling (our co-primary outcomes). Most studies examining different bowel preparation and NPO status were not adequately powered to detect aspirations requiring hospitalizations or designed to assess rescheduling due to NPO status.

Hospital- or population-based studies that reported on aspiration for individuals undergoing colonoscopy with sedation did not report NPO status. The largest study, and the only one conducted in the US, reported on patients age 66 and older (mean age 75 years). The applicability of results to younger individuals is uncertain, though the reported percentage may overestimate aspiration risk. Participants likely had wide ranges of NPO status timing, especially time from NPO to colonoscopy longer than 2 to 4 hours. Thus it is difficult to determine from these studies if and by how much aspiration risk may be effected by varying NPO status.

Definitions of aspiration methods for diagnosing aspiration varied. We were limited to reporting what was provided in published articles.

Many studies excluded patients with serious comorbidities. Few studies recorded mean or range of NPO status timing (including time of last ingestion of water, clear liquids, or bowel preparation substance). Furthermore, only 26 of 40 included studies reported on use of sedation during colonoscopy.

Populations enrolled in eligible studies were broadly applicable to many individuals undergoing elective colonoscopy in the United States. Eligible studies typically included patients 45 to 65 years with approximately 50% of patients enrolled in studies done in the US. Nearly one-half of patients were male and two-thirds of colonoscopies were performed for cancer screening. The largest study reporting on aspirations requiring hospitalization was completed in a US Medicare population. However, aspiration by NPO status was not provided in this study and few other studies were adequately designed to directly assess the role of NPO status on aspirations requiring hospitalizations or colonoscopy rescheduling.

## RESEARCH GAPS/FUTURE RESEARCH

Our findings indicate important gaps including: 1) accurate assessment of aspiration requiring hospitalization and other serious anesthesia-related adverse events according to NPO status, 2) extent of and reasons for variation in anesthesia NPO status practice and policy, 3) effect of NPO status on procedure rescheduling and patient adherence and satisfaction, and 4) reasons for reduced patient adherence to recommendations for NPO status and bowel preparation.

Future studies to close these knowledge gaps could improve care quality. Studies are needed that systematically assess duration of NPO status in relation to timing of colonoscopy and record serious adverse events, such as aspiration requiring hospitalization, with standardized diagnostic criteria. This can be done through setting up prospective registries of Veterans undergoing colonoscopy to record timing of preparation, duration of NPO, and sedation procedures, and then tracking adverse events over the next 48 to 72 hours. Reporting of anesthesia-related complications is required per VHA and Joint Commission policy, and most VA medical centers have electronic reporting systems in place. Future efforts could be directed towards developing standard methods to collate this information and initiate analyses to assess the association of duration of NPO and colonoscopy outcome. In this regard, special populations at higher risk of aspiration and other anesthesia-related outcomes would be of particular interest, such as elderly patients, patients with high comorbidities, and those with disabilities that limit ability to follow and complete the bowel preparation instructions.

Future studies are also needed to determine and understand variability in NPO duration policies and practices across VA (especially practices that may not adhere to national society guidance statements) and to implement interventions to reduce variation. There is also a need to evaluate the effect of variable durations of NPO status prior to colonoscopy on patient satisfaction, adherence to colonoscopy, and impact on endoscopy scheduling processes, including delays in timely receipt of colonoscopy. A better understanding of why some patients do not adhere to NPO status recommendations and methods to improve communication and adherence are needed. Alternative scheduling methods, including later but same day colonoscopy, could also be evaluated to reduce “cancellations” due to NPO non-adherence. Colonoscopy without moderate or deep sedation, commonly used in other developed countries, could be offered to some patients, though concerns exist regarding patient comfort and colonoscopy quality.

National and international multi-society (gastroenterology, gastrointestinal endoscopy, colon and rectal surgery, and gastrointestinal and endoscopic surgery) guidelines5,7,63 now recommend using split-dose regimens for bowel preparation, such that the second dose of laxative is administered 4 to 6 hours before the colonoscopy, with completion at least 2 hours before the exam. Additionally, the ASA guidelines support NPO of 2 hours after clear liquids.10 However, there is a need for larger studies comparing shorter durations of NPO prior to colonoscopy (such as 2 to 4 hours) to longer intervals of NPO prior to colonoscopy (such as ≥ 6 hours) that directly assess for colonoscopy effectiveness (such as detection rate of adenoma and neoplasia, completion rate) and safety outcomes (including aspiration). We also need studies evaluating the effect of variable duration of NPO status prior to colonoscopy on patient satisfaction, adherence to colonoscopy, and impact on endoscopy scheduling processes, including delays in timely receipt of colonoscopy.

Finally, evidence-based multi-society consensus guidelines are needed that bring together patient representatives and members from anesthesia, gastroenterology, and general medicine. Recommendations for NPO status also affect other gastroenterology procedures as well as procedures performed by other specialties (eg, pulmonary and cardiology). Therefore, including representatives across a wide range of disciplines and procedures would be helpful in developing evidence-based recommendations targeted to specific procedures and likely benefits and harms. Important items in guideline development include determining the “clinically important” balance between critical outcomes to anesthesiologists, gastroenterologists (and other specialty groups performing procedures), and patients, including aspiration rates due to NPO status, colonoscopy quality measures, resource use, and patient satisfaction and adherence.

## CONCLUSIONS

Aspiration incidence requiring hospitalization during colonoscopy with moderate or deep sedation is very low and on the order of magnitude commonly accepted for adverse effects of similar clinical importance due to other elective procedures. Participants in hospital- and population-based studies likely had wide ranges of timing from NPO to colonoscopy and many were likely longer than 2 to 4 hours. No study documenting NPO status found that shorter NPO status prior to colonoscopy increased aspiration risk. We did not find direct evidence of the effect of NPO status on colonoscopy rescheduling. Shorter time from completion of colonic preparation to colonoscopy is associated with greater bowel preparation quality than longer time intervals.