# RESULTS

## LITERATURE FLOW

Our literature search yielded 1177 abstracts or titles (Figure 1). After reviewing the abstracts we excluded 1069 and performed full text review of 108 articles. We excluded 74 articles and included 34. A hand-search of reference lists of guidelines, existing reviews, and included studies yielded another 6 articles for a total of 40 included studies of different bowel preparation or NPO status intervals (28 RCTs, 2 controlled CCTs, and 10 observational studies).

Figure 1 Literature Flow Chart

## OVERVIEW

Baseline characteristics for the 40 RCTs, CCTs, and observational studies13-53 reporting outcomes of interest are presented in Table 1. A total of 22,936 patients were evaluated; approximately one-half of the patients were from the United States or Canada. Mean age was 57 years in the 34 studies reporting. Sixty-one percent of colonoscopies were screening colonoscopies. Detailed study characteristics and risk of bias criteria are presented in Appendix C, Table 1.

Table 1 Summary of Baseline Characteristics

Characteristic | Mean (range) Unless Otherwise Noted | Number of Studies Reporting
Total number of patients evaluated | 22,936 (80 to 5175) | 40
Randomized controlled trials, number of patients | 9304 (80 to 895) | 28
Controlled clinical trials, number of patients | 740 (328 to 412) | 2
Observational studies, number patients | 12,892 (100 to 5175) | 10
Age of subjects, years (range of means) | 57 (44 to 63) | 34
Age of subjects, range of median years | 55 to 65 | 3
Gender, male, % of patients | 46 (28 to 81) | 38
Indication for colonoscopy-screening, % of patients | 61 (0^a^ to 100) | 20
Location - USA/Canada, number of patients | 12,208 (100 to 5175) | 17
Location - Asia/Australia, number of patients | 8045 (80 to 3079) | 14
Location - Europe, number of patients | 2683 (160 to 895) | 9

a Two studies reported that screening was not an indication for colonoscopy. Chiu 2006^20^ included participants who had colorectal neoplasms detected at a screening colonoscopy and were scheduled for a second colonoscopic examination for either elective polypectomy or endoscopic mucosectomy. Manno 2012^40^ included participants with a positive fecal occult test or those in surveillance post-polypectomy.

From each included study, we identified a minimum time from the end of preparation until the procedure. Three studies36,38,43 did not provide enough information to determine a minimum time. We also extracted information about timing of liquids allowed prior to the procedure from the 11 studies that reported that information. Figure 2 displays the minimum times based on bowel preparation time and the time before the procedure that clear liquids were allowed.

Figure 2 Minimum Time from End of Bowel Preparation to Procedure (Blue Lines) or Time Before Procedure when Liquids were Stopped (Red Lines)^a^ a 3 studies did not provide sufficient information to determine a minimum time from end of preparation to procedure (Khan 2010,36 Kolts 1993,38 Mathus-Vliegen 2013^43^) ,^b^ b Studies where patients were allowed liquids until time of procedure are indicated by a time of 0.25 hours ,^c^ c Citations are author, year (reference number)

An overview of outcomes reported in each study is presented in Table 2. An NPO status of > 8 hours indicates that the bowel preparation was completed the night before colonoscopy but the exact time of completion and time of colonoscopy were not reported. Our predefined primary and secondary outcomes were rarely reported. Six studies reported our co-primary outcome of aspiration29,31,41,43,44,52; one reported rescheduled colonoscopies.38 Of our secondary and intermediate outcomes, all but one study reported quality of the bowel preparation. Few studies reported other adverse events, diagnostic yield, completion rates, adenoma detection rate, total procedure time, cecal intubation time, withdrawal time, patient adherence, patient satisfaction, or volume of gastric contents. No studies reported false negative colonoscopies, hospitalizations, costs, unused procedure slots, delays in rescheduling, delays in diagnosis, increased volume of procedures, scheduler and nursing time, or acidity of the gastric contents. Detailed outcome data are presented in Appendix C, Tables 2 through 6.

Table 2 Overview of Outcomes Reported

Author, Year NPO Status Groups^a^ | Primary Outcomes | | Secondary Outcomes | | | | | | Intermediate Outcomes
Author, Year NPO Status Groups^a^ | Aspiration (k=6) | Rescheduled Colonoscopies (k=1) | Bowel Perforation (k=1) | Other Adverse Events (k=7) | Diagnostic Yield (k=3) | Completion Rate (k=11) | Adenoma Detection Rate (k=7) | False Negative Colonoscopy | Hospitalizations | Costs | Quality of Bowel Preparation (k=39) | Total Procedure Time (k=3) | Cecal Intubation Time (k=4) | Withdrawal Time (k=5) | Patient Adherence (k=11)^b^ | Patient Satisfaction (k=11) b | Unused Procedure Slots | Delays, Rescheduling | Delays, Diagnosis | Increased Volume, Procedures | Scheduler/Nurse Time | Volume of Gastric Contents (k=2) | | pH of Gastric Contents
Abdul-Baki 2008^13^ Group 1: ≥ 1.5 hours Group 2: > 8 hours | | | | | | | | | | | ✓ | | | | ✓ | ✓
Aoun 2005^14^ Group 1: ≥ 1.5 hours Group 2: > 8 hours | | | | | | | | | | | ✓ | | | | ✓ | ✓ | | | | | | ✓
Arya 2013^15^ Group 1: ≥ 2 hours Group 2: > 8 hours | | | | | | | | | | | ✓
Athreya 2011^16^ Group 1: 5-9 hours Group 2: > 8 hours | | | | | | | | | | | ✓ | ✓ | ✓ | ✓
Barclay 2004^17^ Group 1: < 3 hours Group 2: ≥ 5 hours | | | | ✓ | | | | | | | ✓ | | | | ✓ | ✓
Bryant 2013^18^ Group 1: 5-7.5 hours Group 2: > 8 hours | | | | | | | | | | | ✓
Chiu 2011^19^ Group 1: 5-9 hours Group 2: >8 hours | | | | | | | ✓ | | | | ✓
Chiu 2006^20^ Group 1: 6-8 hours Group 2: > 8 hours | | | | | ✓ | ✓ | | | | | ✓
Church 1998^21^ Group 1: 5-8 hours Group 2: > 8 hours | | | | ✓ | | ✓ | | | | | ✓ | | ✓ | ✓
De Salvo 2006^22^ Group 1: 5-8 hours Group 2: >8 hours | | | | | | ✓ | | | | | ✓
Di Palma 2011^23^ Group 1: 3-9 hours Group 2: > 8 hours | | | | | | | | | | | ✓
El Sayed 2003^24^ Group 1: ≥ 2 hours Group 2: > 8 hours | | | | | | | | | | | ✓
Eun 2011^25^ Group 1: ≥ 1 hour Group 2: > 7 hours | | | | | | | | | | | ✓ | | | | ✓
Flemming 2012^26^ Group 1: ≥ 4 hours Group 2: > 8 hours | | | ✓ | ✓ | | ✓ | | | | | ✓
Frommer 1997^27^ Group 1: 3-9 hours Group 2: > 8 hours | | | | | | | | | | | ✓
Gupta 2007^28^ Group 1: ≥5 hours Group 2: > 8 hours | | | | | | | | | | | ✓ | | | | | ✓
Gurudu 2010^29^ Group 1: ≥ 4 hours Group 2: > 8 hours | ✓ | | | | | | ✓ | | | | ✓
Gurudu 2012^30^ Group 1: ≥ 4 hours Group 2: > 8 hours | | | | | | ✓ | ✓ | | | | ✓ | | | ✓
Huffman 2010^31^ Group 1: ≥ 2 hours Group 2: > 8 hours | ✓ | | | | | | | | | | | | | | | | | | | | | ✓
Johanson 2007^32^ Group 1: 2.5-4.5 hours Group 2: > 8 hours | | | | ✓ | | | | | | | ✓
Kao 2011^33^ Group 1: 4-8 hours Group 2: > 8 hours | | | | | | | | | | | ✓
Kastenberg 2001, 2007^34,35^ Group 1: 2-4 hours Group 2: > 8 hours | | | | | | ✓ | | | | | ✓
Khan 2010^36^ Group 1: Split-dose^c^ Group 2: > 8 hours | | | | | | | | | | | ✓
Koh 2011^37^ Group 1: 1.5-3.5 hours Group 2: 6-8 hours | | | | | | | | | | | ✓
Kolts 1993^38^ Group 1: Split-dose^c^ Group 2: > 8 hours Group 3: > 8 hours | | ✓ | | | | | | | | | ✓
Kössi, 2007^39^ Group 1: ≤ 6 hours Group 2: 6-12 hours Group 3: ≥ 12 hours | | | | | | ✓ | | | | | ✓ | | | | | ✓
Longcroft-Wheaton 2012^40^ Group 1: > 3 hours Group 2: > 5 hours | | | | | | | ✓ | | | | ✓ | | | | ✓ | ✓
Manno 2012^41^ Group 1: 2 hours Group 2: >8 hours | ✓ | | | | | | | | | | ✓ | | | | ✓ | ✓
Marmo 2010^42^ Group 1: ≤ 2 hours Group 2: >8 hours | | | | | | ✓ | | | | | ✓
Mathus-Vliegen 2013^43^ Group 1: Split-dose^c^ Group 2: > 8 hours | ✓ | | | ✓ | | | | | | | ✓
Matro 2010^44^ Group 1: 4 hours Group 2: 4 hours (split-dose) | ✓ | | | | ✓ | ✓ | ✓ | | | | ✓ | ✓ | | ✓ | ✓ | ✓
Paoluzi 1993^45^ Group 1: 1-2.5 hours Group 2: > 8 hours | | | | | | | | | | | ✓
Park 2007^46^ Group 1: ≥ 2 hours Group 2: > 8 hours | | | | | | | | | | | ✓ | | ✓ | | ✓ | ✓
Park 2010^47^ Group 1: 2-5 hours Group 2: > 8 hours | | | | | | | | | | | ✓ | | | | ✓ | ✓
Parra-Blanco 2006^48^ Group 1: 1.7-7 hours Group 2: > 8 hours | | | | | ✓ | | ✓ | | | | ✓
Rex 2013^49^ Group 1: 5-9 hours Group 2: > 8 hours | | | | ✓ | | ✓ | | | | | ✓ | | | | ✓
Seo 2012^50^ Group 1: ≤ 3 hours Group 2: > 8 hours | | | | | | | | | | | ✓
Vanner 2011^51^ Group 1: > 5 hours Group 2: > 8 hours | | | | | | ✓ | | | | | ✓
Varughese 2010^52^ Group 1: ≥ 3 hours Group 2: > 8 hours | ✓ | | | | | | ✓ | | | | ✓ | ✓ | ✓ | ✓ | ✓ | ✓
Voiosu 2013^53^ Group 1: 1-7 hours Group 2: > 8 hours | | | | ✓ | | | | | | | ✓

a NPO status > 8 hours indicates bowel preparation completed the night before colonoscopy but exact time of completion and time of colonoscopy not reported

b Data on patient adherence and patient satisfaction extracted only from studies using same bowel preparation substance in the study groups (k=21)

c Time of morning dose or time of colonoscopy not reported

## KEY QUESTION 1 Does the incidence of aspiration and other anesthesia-related harms for colonoscopy vary by NPO status or bowel prep timing (eg, > 6 hours, 2-6 hours, < 4 hours, and < 2 hours)? Does the incidence of anesthesia-related harms by NPO status vary by: A) Patient characteristics (age, race, sex, obesity, comorbidities) B) Sedation (moderate, deep)?

### Findings from Trials of Different Bowel Preparation Protocols

#### Aspiration Risk (Appendix C, Table 2)

Six studies reported on aspiration (sample sizes ranged from 136 to 1,345).29,31,41,43,44,52 In 5 of these studies no aspirations occurred during colonoscopy29,31 or during colonoscopy or within the 30 days post-colonoscopy,43 or there were no complications related to sedation.41,52

One observational study (moderate risk of bias) reported no aspiration events in 1,345 patients.29 Bowel preparation regimens were completed either the morning of the procedure (at least 4 hours prior to colonoscopy) or the evening before the colonoscopy. All patients were allowed to drink clear liquids up to 3 hours before the procedure.

The second study, also observational and moderate risk of bias, enrolled 301 patients.31 One group completed bowel preparation at least 2 hours before the procedure (mean NPO time of 5.1 hours). The second group completed bowel preparation the evening before (mean NPO time of 13.5 hours). No patient had “clinical evidence” of aspiration. The volume of the gastric contents did not differ significantly.

One RCT used medical charts and a complications database to identify aspiration events during colonoscopy or in the 30 days following colonoscopy for 200 patients.43 No events were reported.

The 2 studies reporting no complications related to sedation were both RCTs with enrollments of 136^52^ and 336^41^ respectively. In the first study, with moderate risk of bias, patients in one group completed preparation by 10 am for an afternoon colonoscopy (1 pm or later); the other group completed preparation the night before the procedure.52 Both groups were allowed clear liquids until 10 am. In the second study, with low risk of bias, one group completed preparation 2 hours before the procedure and the other group completed preparation the day before.41

One small (n=125 randomized), low risk of bias RCT reported one aspiration event requiring hospitalization during colonoscopy under moderate sedation.44 The patient was described as severely obese (BMI = 40 kg/m^2^) but with no other obvious risk factors for aspiration. The patient was assigned to consume 1 L of a bowel preparation agent 7 hours before colonoscopy and an additional 1 L 4 hours before. Patients in this trial were allowed clear liquids until 2.5 hours before the procedure. The patient was hospitalized for 24 hours and treated with oral antibiotics for one week.

#### Other Harms (Appendix C, Table 5)

Seven studies (6 moderate risk of bias, 1 low risk of bias) reported on other harms. In 4 studies, there were no adverse events, specifically no complications of bowel perforation or bleeding up to the time of leaving the endoscopy office26 or no serious adverse events.17,21,53 One of these studies interviewed patients 2 days post-colonoscopy,17 one recorded adverse events through approximately 2 hours post-colonoscopy,53 and one did not provide a timeframe.17

Three studies reported adverse events with harms occurring in less than or equal to 1% of procedures. In 2 studies, there was one event in the longer NPO status group and no events in the shorter NPO status group.32,43 One RCT with 402 patients reported lower gastrointestinal bleeding post-colonoscopy in one patient (0.5%) who completed bowel preparation more than 8 hours before colonoscopy.32 Another RCT, with 200 patients, reported severe retrosternal pain in one patient (1%) 3 hours after the colonoscopy. Anteroseptal infarction was diagnosed. The patient was in the group that had morning colonoscopies following bowel preparation completed the evening before.43 A third RCT, with 603 patients, reported acute pancreatitis in one patient (0.3%) who completed bowel preparation between 5-9 hours before colonoscopy and non-cardiac chest pain in one patient (0.3%) who completed bowel preparation more than 8 hours before colonoscopy.49 It was unclear if these events occurred during bowel preparation, during colonoscopy, or post-colonoscopy. The study included follow-up visits at 24 to 48 hours, one week, and 4 weeks.

#### Gastric Volume and Acidity (Appendix C, Table 6)

Two studies reported no difference in volume of gastric contents. In one low risk of bias RCT,14 141 patients were assigned to complete bowel preparation the morning of and at least 1.5 hours prior to the procedure or the evening before the procedure. Both groups were allowed water until the time of the procedure. Approximately 25% of patients in each group underwent tandem esophagogastroduodenoscopy (EGD) and gastric volume was assessed. The second study was a moderate risk of bias observational study.31 The split-dose preparation group completed preparation by 2 hours prior to the procedure. Findings were compared to a group that completed bowel preparation the day before the colonoscopy; additional clear fluids were allowed “as desired.” EGD was performed immediately before colonoscopy for both groups. No study reported the acidity of the gastric contents.

### Additional Studies of Aspiration during Colonoscopy

Several hospital- or population-based studies have also reported on aspiration during colonoscopy. However, none documented duration of NPO status prior to the colonoscopy. In a large database study, the incidence of aspiration requiring hospitalization during 165,527 outpatient diagnostic colonoscopies in 100,359 Medicare patients age 66 years and older (mean age = 76 years) was 0.14% for patients having colonoscopy under deep sedation requiring anesthesia assistance (as identified by a CPT-4 code) and 0.10% for patients under moderate sedation without anesthesia assistance.54 A study of 23,508 outpatient colonoscopies at 3 hospitals in Australia reported one case (0.004%) of aspiration requiring hospitalization in a patient undergoing colonoscopy with general anesthesia.55 A study of 3,155 colonoscopies performed with sedation managed by an anesthesiologist in adults at a single hospital in Italy reported that 0.16% of patients undergoing colonoscopy had an aspiration requiring “some intervention by an anesthesiologist.”56 Aspirations requiring hospitalizations were not reported.

Patients were instructed to fast according to guidelines in place at the time – clear liquids up to 2 hours before the procedure and a light meal (toast and clear liquid) up to 6 hours before the procedure.

## KEY QUESTION 2 What is the effect of variable timing of bowel prep and NPO status on the quality of the bowel preparation, diagnostic yield, and colonoscopy procedural quality indicators (eg, completion rates, adenoma detection rate, total procedure time, cecal intubation time and withdrawal time)?

### Quality of the Bowel Preparation

Thirty-nine studies (28 RCTs, 2 CCTs, and 9 observational studies) reported on the effect of variable timing of bowel preparation on quality of the bowel preparation (Appendix C, Table 3).13-30,32-53 Eleven of these studies (6 RCTs, 1 CCT, 4 observational) also reported the time prior to colonoscopy when water or other clear liquids were allowed, ranging from 4 hours until the time of the procedure.13,14,16,18,21,29,30,33,44,50,52 Although different rating scales were used to rate the quality of the bowel preparation, quality of the bowel preparation was consistently rated higher for NPO intervals of 6 hours or less compared to intervals of more than 8 hours.

Of the 28 studies (n=11,698) that only reported timing of bowel preparation and compared shorter (1-6 hours) versus longer intervals (8-12 hours) between bowel preparation administration and colonoscopy, 21 reported significantly higher quality of bowel preparation with a shorter interval between preparation and colonoscopy and 7 reported no significant difference.

Limited data suggest that consumption of water or clear liquids, including preparation solutions, from 0 to 4 hours prior to colonoscopy does not affect quality of the bowel preparation. Of the 11 studies (n=10,931) reporting timing of liquid consumption, 3 allowed water or other clear liquids up to the time of the procedure and 2, 1, 3, and 2 studies allowed water intake up to 2 hours, 2.5 hours, 3 hours, and 4 hours prior to colonoscopy, respectively. Nine studies reported significantly higher quality rating of the preparation in the group completing bowel preparation less than 8 hours prior to colonoscopy (minimum NPO status based on bowel preparation of 1.5 to 6 hours) compared to the group completing bowel preparation more than 8 hours prior to colonoscopy. One study reported no significant difference in quality of preparation between groups completing bowel preparation the morning of the colonoscopy or in a split-dose (evening before/morning of colonoscopy). Both groups completed bowel preparation 4 hours prior to colonoscopy. The remaining study reported higher quality in the shorter NPO duration group but no statistical analysis was possible.

### Other Secondary or Intermediate Outcomes

Few studies reported other secondary or intermediate outcomes.

#### Diagnostic yield (k=3) (Appendix C, Table 3; Figure 3)

Figure 3 Completion Rate, Adenoma Detection Rate, and Diagnostic Yield: Outcomes from Randomized Controlled Trials

One moderate risk of bias RCT (n=121) reported a significantly higher total number of lesions detected in patients with who completed bowel preparation 6 to 8 hours before colonoscopy compared to more than 8 hours (2.8 vs 1.9, P = .03).20 No differences were noted for either proximal lesions or advanced lesions. All patients in this study had colon neoplasms detected during a previous colonoscopy.

A second moderate risk of bias RCT (n=197) reported a significantly greater yield of flat lesions in patients who completed bowel preparation 1 to 7 hours before colonoscopy compared to those who completed preparation more than 8 hours before (22% vs 9%, P < .05); no difference were reported for “any polyp” (52% vs 45%) or “protruding polyps” (40% vs 42%).48

A low risk of bias RCT (n=125) reported significantly more “findings” (adenoma or cancer) per patient (0.70 vs 0.46, P = .047) in the group that completed bowel preparation in the morning compared to a group that used a split-dose protocol.44 Both groups completed the preparation 4 hours prior to colonoscopy and were allowed clear liquids up to 2.5 hours before the procedure.

#### Completion rates (k=11) (Appendix C, Table 3; Figure 3; Figure 4)

Figure 4 Completion Rate and Adenoma Detection Rate: Outcomes from Observational Studies

Results from 5 RCTs providing sufficient information to permit pooling found no difference in completion rates between shorter and longer NPO status (RR 1.00 [95%CI 0.98, 1.01).20-22,26,34

One additional low risk of bias RCT (n=895) reported an overall completion rate of 95% but significantly fewer aborted procedures due to inadequate bowel preparation when the preparation was completed 2 hours or less before colonoscopy (93%) compared to more than 8 hours before colonoscopy (79%).42

A high risk of bias observational study (n=5,175) reported a significantly higher colonoscopy completion rate in patients completing bowel preparation 4 hours or more before colonoscopy (96%) compared to 8 hours or more (94%). Patients in both groups were allowed liquids until 3 hours before the procedure.30

Another study, a low risk of bias RCT not included in the figure because both groups completed bowel preparation 4 hours before colonoscopy, reported no significant difference in completion rate between the single dose (98%) or split-dose (100%) groups.44

Three studies provided completion rates but did not report separate results for the NPO status groups: a moderate sized RCT,49 a moderate sized observational study,39 and a small observational study.51 The completion rates were 96%,39 99%,49 and 95%.51

#### Adenoma detection rate (k=7) (Appendix C, Table 3; Figure 3; Figure 4)

One high risk of bias observational study (n=5,175) reported a significantly higher adenoma detection rate of in patients who completed bowel preparation 4 hours or more before colonoscopy compared to those completing preparation more than 8 hours before (32% vs 27%, P < .001).30 All patients in this study were allowed liquids until 3 hours prior to the procedure. Another observational study (n=3,079, moderate risk of bias) found significantly higher detection of proximal adenomas in patients who completed bowel preparation 5 to 9 hours before colonoscopy compared to more than 8 hours (11% vs 9%, P = .04) although overall detection did not differ (17% vs 15%, P = .11).19 Four studies (3 moderate risk of bias, 1 low risk of bias) reported no difference in detection rate between groups with shorter versus longer times between completion of bowel preparation and the procedure.29,40,48,52 One of the studies allowed liquids until 3 hours prior to the procedure.29

In the study comparing single dose to split-dose preparation, both completing preparation 4 hours before colonoscopy with liquids allowed until 2.5 hours before, the overall detection rate was higher in the morning-only preparation group (37% vs 25%, P = .04).44 For high-risk adenoma or cancer, the difference was not significantly different (13% vs 11%, P = .28).

#### Total procedural time (k=3) (Appendix C, Table 4)

Total procedure time, reported in 3 studies, did not differ between groups. In one high risk of bias CCT (n=325) completion of bowel preparation 5 to 9 hours before the procedure was compared to preparation the night before.16 In the second study, a moderate risk of bias RCT (n=136), bowel preparation was completed 3 hours or more before the procedure compared to more than 8 hours.52 The third study, a low risk of bias RCT (n=125), compared morning-only preparation to split-dose preparation.44 One of these studies allowed patients to consume clear fluids up to 4 hours before the procedure16 and another up to 2.5 hours before the procedure.44 The other study required all patients to be NPO after 10 am for an afternoon colonoscopy.52

#### Cecal intubation time (k=4) (Appendix C, Table 4)

One low risk of bias RCT (n=303) reported shorter cecal intubation time (a measure of higher bowel preparation and colonoscopy quality) in patients who completed bowel preparation at least 2 hours before colonoscopy compared to more than 8 hours.46 Times did not differ in the 2 other, moderate risk of bias, RCTs (n=453)21,52 or the CCT (n=325)16 reporting this outcome. In one of the RCTs finding no difference, patients were allowed water until the time of the procedure.21 The other 2 studies (1 moderate risk of bias RCT, 1 high risk of bias CCT) allowed clear fluids until 4 hours before the procedure16 or required patients to be NPO after 10 am prior to an afternoon colonoscopy.52

#### Withdrawal time (k=5) (Appendix C, Table 4)

One high risk of bias observational study (n=5,175) reported a shorter withdrawal time (a measure of higher bowel preparation and colonoscopy quality) in patients with a time from completion of bowel preparation of 4 hours or greater compared to more than 8 hours (12 minutes vs 15 minutes, P < .001).30 Patients were allowed clear liquids until 3 hours before colonoscopy. Three other studies (1 low risk of bias RCT, 2 moderate risk of bias RCTs, and one high risk of bias CCT) reporting withdrawal time found no difference between shorter and longer NPO intervals16,21,52 or between morning-only and split-dose preparation.44 One RCT allowed water until the time of the procedure, one RCT allowed clear liquids up to 2.5 hours before the procedure, one RCT required patients to be NPO after 10 am for an afternoon procedure, and the CCT allowed clear fluids until 4 hours before colonoscopy.

## KEY QUESTION 3 What is the effect of NPO status prior to colonoscopy on resource use (eg, costs, unused procedure slots, delays in rescheduling, delays in diagnosis, increased volume of procedures, scheduler and nursing time associated with cancelled or delayed procedures)?

One moderate risk of bias RCT reported rescheduled colonoscopies.38 The percentage of rescheduled colonoscopies was significantly lower (P = .011) in the group that completed bowel preparation on the morning of the procedure (3%) taking a split-dose of a sodium phosphate regimen than in groups consuming a polyethylene glycol solution (8%) or a castor oil solution (24%) the evening before the procedure. Differences in the bowel preparation solutions between groups limit our ability to draw firm conclusions about the role of NPO status on rescheduling.

No other study reported resource use. Although some studies reported inadequate bowel preparation quality, they did not report whether the colonoscopy was repeated.

## KEY QUESTION 4 What is the effect of bowel preparation and NPO status prior to colonoscopy on patient adherence to bowel preparation, colonoscopy, and/or rescheduled colonoscopy and satisfaction with bowel preparation and/or colonoscopy?

Data are limited on the effect of bowel preparation and NPO status on patient adherence, colonoscopy rescheduling, and satisfaction. We extracted data on adherence and satisfaction from studies where the same bowel preparation substance (eg, polyethylene glycol) was used for all patients (Appendix C, Table 4). Compared to a same-day regimen (completed the day before colonoscopy), a split-dose regimen was associated with greater adherence to bowel preparation in 4 studies13,14,41,46 with a significantly greater adherence in 2 of those studies, both low risk of bias RCTs.13,14 Two studies, one low risk of bias observational study and one moderate risk of bias RCT, that included a dose on the day of the procedure for all patients reported better completion of the preparation in patients who finished the preparation closer to the time of the procedure (approximately 3 hours vs 5 hours or more in both studies).17,40 A third study, a low risk of bias observational study, reported no difference between groups completing bowel preparation less than 4 versus more than 4 hours prior to colonoscopy.25 Three studies, high, moderate, and low risk of bias RCTs, reported no difference in compliance with a split-dose regimen compared to a same day regimen.44,47,52 One low risk of bias RCT reported treatment-emergent adverse events leading to discontinuation of the preparation in 2 of 603 patients (0.3%) with no difference between the split-dose or same-day groups.49

We extracted elements of satisfaction that would be impacted by different schedules for bowel preparation (Appendix C, Table 4). Five studies reported on work or school time lost. Two low risk of bias RCTs found no difference in the percentage of patients reporting work or school time missed between split-dose and same-day groups.13,14 Another low risk of bias RCT reported that 85% of the morning-only preparation group compared to 55% of the split-dose group (P = .019) reported no interference with work on the day before the procedure. One moderate risk of bias RCT reported significantly fewer hours lost form work with a split-dose regimen.28 The fourth study, a low risk of bias observational study, reported that completion of the bowel preparation regimen closer to the time of the procedure (3 hours or more compared to 5 hours or more) caused less interruption of sleep.40

Eight studies reported on sleep disturbance. Two moderate risk of bias RCTs found less sleep disruption in patients on a split-dose protocol28,52 and a third low risk of bias observational study found less sleep disruption with a protocol that required completion of the preparation regimen closer to the procedure time (3 hours or more compared to 5 hours or more).40 Five RCTs, 3 low and 1 high risk of bias, found no difference in sleep disruption between split-dose and same-day regimens.13,14,44,45,47 One low risk of bias observational study reported no differences in difficulty traveling to the colonoscopy among patients who completed the preparation fewer than 6 hours (3.8%), 6 to 12 hours (5.6%), or more than 12 hours (4.9%) before the procedure.39