# REFERENCES

1 Faiss S. The missed colorectal cancer problem. Digestive Diseases. 2011;29(Suppl 1):60-3. [pmid: 22104756].
2 Chokshi RV, Hovis CE, Hollander T, Early DS, Wang JS. Prevalence of missed adenomas in patients with inadequate bowel preparation on screening colonoscopy. Gastrointest Endosc. 2012;75(6):1197-203. [pmid: 22381531].
3 Rex DK, Imperiale TF, Latinovich DR, Bratcher LL. Impact of bowel preparation on efficiency and cost of colonoscopy. Am J Gastroenterol. Jul. 2002;97(7):1696-700. [pmid: 12135020].
4 Kilgore TW, Abdinoor AA, Szarzy NM, et al. Bowel preparation with split-dose polyethylene glycol before colonoscopy: a meta-analysis of randomized controlled trials. Gastrointest Endosc. 2011;73:1240-5. [pmid: 21628016].
5 Hassan C. Bowel preparation for colonoscopy: European Society of Gastrointestinal Endoscopy (ESGE) Guideline. Endoscopy. 2013;45(2):142-50. [pmid: 23335011].
6 Mathus-Vliegen E, Pellisé M, Heresbach D, et al. Consensus guidelines for the use of bowel preparation prior to colonic diagnostic procedures: colonoscopy and small bowel video capsule endoscopy. Curr Med Res Opin. 2013;29:931-45. [pmid: 23659560].
7 Johnson DA, Barkun AN, Cohen LB, et al. Optimizing adequacy of bowel cleansing for colonoscopy: recommendations from the U.S. Multi-Society Task Force on Colorectal Cancer. Gastrointest Endosc. 2014;80(4):543-62. [pmid: 25220509].
8 Cohen LB, Wecsler JS, Gaetano JN, et al. Endoscopic sedation in the United States: results from a nationwide survey. Am J Gastroenterol. May. 2006;101(5):967-74. [pmid: 16573781].
9 Standards of Practice Committee of the American Society for Gastrointestinal Endoscopy, Lichtenstein DR, et al. Sedation and anesthesia in GI endoscopy. Gastrointest Endosc. 2008;68:815-26. [pmid: 18984096].
10 American Society of Anesthesiologists. Practice guidelines for pre-operative fasting and the use of pharmacologic agents to reduce the risk of pulmonary aspiration: Application to healthy patients undergoing elective procedures. Anesthesiology. 2011;114:495-511. [pmid: 21307770].
11 Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0. [updated March 2011]. The Cochrane Collaboration. 2011. Available from www.cochrane-handbook.org.
12 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--Agency for Healthcare Research and Quality and the Effective Health-Care Program. J Clin Epidemiol. 2010;63(5):513-23. [pmid: 19595577].
13 Abdul-Baki H, Hashash JG, Elhajj II, Azar C, El Zahabi L, Mourad FH, et al. A randomized, controlled, double-blind trial of the adjunct use of tegaserod in whole-dose or split-dose polyethylene glycol electrolyte solution for colonoscopy preparation. Gastrointest Endosc. 2008;68(2):294-300. [pmid: 18511049].
14 Aoun E, Abdul-Baki H, Azar C, Mourad F, Barada K, Berro Z, et al. A randomized single-blind trial of split-dose PEG-electrolyte solution without dietary restriction compared with whole dose PEG-electrolyte solution with dietary restriction for colonoscopy preparation. Gastrointest Endosc. 2005;62(2):213-8. [pmid: 16046981].
15 Arya V, Gupta KA, Valluri A, Arya SV, Lesser ML. Rapid colonoscopy preparation using bolus lukewarm saline combined with sequential posture changes: a randomized controlled trial. Dig Dis Sci. 2013;58(8):2156-66. [pmid: 23456498].
16 Athreya PJ, Owen GN, Wong SW, Douglas PR, Newstead GL. Achieving quality in colonoscopy: bowel preparation timing and colon cleanliness. ANZ J Surg. 2011;81(4):261-5. [pmid: 21418470].
17 Barclay RL. Safety, efficacy, and patient tolerance of a three-dose regimen of orally administered aqueous sodium phosphate for colonic cleansing before colonoscopy. Gastrointest Endosc. 2004;60(4):527-33. [pmid: 15472673].
18 Bryant RV, Schoeman SN, Schoeman MN. Shorter preparation to procedure interval for colonoscopy improves quality of bowel cleansing. Intern Med J. 2013;43(2):162-8. [pmid: 22998352].
19 Chiu HM, Lin JT, Lee YC, Liang JT, Shun CT, Wang HP, et al. Different bowel preparation schedule leads to different diagnostic yield of proximal and nonpolypoid colorectal neoplasm at screening colonoscopy in average-risk population. Dis Colon Rectum. 2011;54(12):1570-7. [pmid: 22067187].
20 Chiu HM, Lin JT, Wang HP, Lee YC, Wu MS. The impact of colon preparation timing on colonoscopic detection of colorectal neoplasms--a prospective endoscopist-blinded randomized trial. Am J Gastroenterol. 2006;101(12):2719-25. [pmid: 17026559].
21 Church JM. Effectiveness of polyethylene glycol antegrade gut lavage bowel preparation for colonoscopy--timing is the key!. Dis Colon Rectum. 1998;41(10):1223-5. [pmid: 9788383].
22 De Salvo L, Borgonovo G, Ansaldo GL, Varaldo E, Floris F, Assalino M, et al. The bowel cleansing for colonoscopy. A randomized trial comparing three methods. Ann Ital Chir. 2006;77(2):143-6. [pmid: 17147088].
23 Di Palma JA, Rodriguez R, McGowan J, Cleveland M. A randomized clinical study evaluating the safety and efficacy of a new, reduced-volume, oral sulfate colon-cleansing preparation for colonoscopy. Am J Gastroenterol. 2009;104(9):2275-84. [pmid: 19584830].
24 El Sayed AM, Kanafani ZA, Mourad FH, Soweid AM, Barada KA, Adorian CS, et al. A randomized single-blind trial of whole versus split-dose polyethylene glycol-electrolyte solution for colonoscopy preparation. Gastrointest Endosc. 2003;58(1):36-40. [pmid: 12838218].
25 Eun CS, Han DS, Hyun YS, Bae JH, Park HS, Kim TY, et al. The timing of bowel preparation is more important than the timing of colonoscopy in determining the quality of bowel cleansing. Dig Dis Sci. 2011;56(2):539-44. [pmid: 21042853].
26 Flemming JA, Vanner SJ, Hookey LC. Split-dose picosulfate, magnesium oxide, and citric acid solution markedly enhances colon cleansing before colonoscopy: a randomized, controlled trial. Gastrointest Endosc. 2012;75(3):537-44. [pmid: 22192423].
27 Frommer D. Cleansing ability and tolerance of three bowel preparations for colonoscopy. Dis Colon Rectum. 1997;40(1):100-4. [pmid: 9102248].
28 Gupta T, Mandot A, Desai D, Abraham P, Joshi A, Shah S. Comparison of two schedules (previous evening versus same morning) of bowel preparation for colonoscopy. Endoscopy. 2007;39(8):706-9. [pmid: 17661245].
29 Gurudu SR, Ratuapli S, Heigh R, DiBaise J, Leighton J, Crowell M. Quality of bowel cleansing for afternoon colonoscopy is influenced by time of administration. Am J Gastroenterol. 2010;105(11):2318-22. [pmid: 21048676].
30 Gurudu SR, Ramirez FC, Harrison ME, Leighton JA, Crowell MD. Increased adenoma detection rate with system-wide implementation of a split-dose preparation for colonoscopy. Gastrointest Endosc. 2012;76(3):603-8. [pmid: 22732876].
31 Huffman M, Unger RZ, Thatikonda C, Amstutz S, Rex DK. Split-dose bowel preparation for colonoscopy and residual gastric fluid volume: an observational study. Gastrointest Endosc. 2010;72(3):516-22. [pmid: 20646700].
32 Johanson JF, Popp JW Jr., Cohen LB, Lottes SR, Forbes WP, Walker K, et al. A randomized, multicenter study comparing the safety and efficacy of sodium phosphate tablets with 2L polyethylene glycol solution plus bisacodyl tablets for colon cleansing. Am J Gastroenterol. 2007;102(10):2238-46. [pmid: 17573796].
33 Kao D, Lalor E, Sandha G, Fedorak RN, van der Knoop B, Doornweerd S, et al. A randomized controlled trial of four precolonoscopy bowel cleansing regimens. Can J Gastroenterol. 2011;25(12):657-62. [pmid: 22175055].
34 Kastenberg D, Chasen R, Choudhary C, Riff D, Steinberg S, Weiss E, et al. Efficacy and safety of sodium phosphate tablets compared with PEG solution in colon cleansing: two identically designed, randomized, controlled, parallel group, multicenter phase III trials. Gastrointest Endosc. 2001;54(6):705-13. [pmid: 11726845].
35 Kastenberg D, Barish C, Burack H, Dalke DD, Duckor S, Putnam W, et al. Tolerability and patient acceptance of sodium phosphate tablets compared with 4-L PEG solution in colon cleansing: combined results of 2 identically designed, randomized, controlled, parallel group, multicenter phase 3 trials. J Clin Gastroenterol. 2007;41(1):54-61. [pmid: 17198066].
36 Khan MA, Piotrowski Z, Brown MD. Patient acceptance, convenience, and efficacy of single-dose versus split-dose colonoscopy bowel preparation. J Clin Gastroenterol. 2010;44(4):310-1. [pmid: 19935082].
37 Koh DH, Lee HL, Kwon YI, et al. The effect of eating lunch before and afternoon colonoscopy. Hepatogastroenterology. 2011;58:775-8. [pmid: 21830388].
38 Kolts BE, Lyles WE, Achem AR, Burton L, Geller AJ, MacMath T. A comparison of the effectiveness and patient tolerance of oral sodium phosphate, castor oil, and standard electrolyte lavage for colonoscopy or sigmoidoscopy preparation. Am J Gastroenterol. 1993;88:1218-23. [pmid: 8338088].
39 Kössi J, Krekelä I, Patrikainen H, Vuorinen T, Luostarinen M, Laato M. The cleansing result of oral sodium phosphate is inversely correlated with time between the last administration and colonoscopy. Tech Coloproctol. 2007;11(1):51-4. [pmid: 17357867].
40 Longcroft-Wheaton G, Bhandari P. Same-day bowel cleansing regimen is superior to a split-dose regimen over 2 days for afternoon colonoscopy: results from a large prospective series. J Clin Gastroenterol. 2012;46(1):57-61. [pmid: 22064553].
41 Manno M, Pigo F, Manta R, Barbera C, Bertani H, Mirante VG, et al. Bowel preparation with polyethylene glycol electrolyte solution: optimizing the splitting regimen. Dig Liver Dis. 2012;44(7):576-9. [pmid: 22456624].
42 Marmo R, Rotondano G, Riccio G, Marone A, Bianco MA, Stroppa I, et al. Effective bowel cleansing before colonoscopy: a randomized study of split-dosage versus non-split dosage regimens of high-volume versus low-volume polyethylene glycol solutions. Gastrointest Endosc. 2010;72(2):313-20. [pmid: 20561621].
43 Mathus-Vliegen EMH, van der Vliet K. Safety, patient's tolerance, and efficacy of a 2-liter vitamin C-enriched macrogol bowel preparation: a randomized, endoscopist-blinded prospective compariston with a 4-liter macrogol solution. Dis Colon Rectum. 2013;56:1002-12. [pmid: 23838870].
44 Matro R, Shnitser A, Spodik M, et al. Efficacy of morning-only compared with split-dose polyethylene glycol electrolyte solution for afternoon colonoscopy: a randomized controlled single-blind study. Am J Gastroenterol. 2010;105:1954-61. [pmid: 20407434].
45 Paoluzi OA, Di Paolo MC, Ricci F, et al. A randomized controlled trial of a new PEG-electrolyte solution compared with a standard preparation for colonoscopy. Ital J Gastroenterol. 1993;25:174-8. [pmid: 8358075].
46 Park JS, Sohn CI, Hwang SJ, Choi HS, Park JH, Kim HJ, et al. Quality and effect of single dose versus split dose of polyethylene glycol bowel preparation for early-morning colonoscopy. Endoscopy. 2007;39(7):616-9. [pmid: 17611916].
47 Park SS, Sinn DH, Kim YH, Lim YJ, Sun Y, Lee JH, et al. Efficacy and tolerability of split-dose magnesium citrate: low-volume (2 liters) polyethylene glycol vs. single- or split-dose polyethylene glycol bowel preparation for morning colonoscopy. Am J Gastroenterol. 2010;105(6):1319-26. [pmid: 20485282].
48 Parra-Blanco A, Nicolas-Perez D, Gimeno-Garcia A, Grosso B, Jimenez A, Ortega J, et al. The timing of bowel preparation before colonoscopy determines the quality of cleansing, and is a significant factor contributing to the detection of flat lesions: a randomized study. World J Gastroenterol. 2006;12(38):6161-6. [pmid: 17036388].
49 Rex DK, Katz PO, Bertiger G, Vanner S, Hookey LC, Alderfer V, et al. Split-dose administration of a dual-action, low-volume bowel cleanser for colonoscopy: the SEE CLEAR I study. Gastrointest Endosc. 2013;78(1):132-41. [pmid: 23566639].
50 Seo EH, Kim TO, Park MJ, Joo HR, Heo NY, Park J, et al. Optimal preparation-to-colonoscopy interval in split-dose PEG bowel preparation determines satisfactory bowel preparation quality: an observational prospective study. Gastrointest Endosc. 2012;75(3):583-90. [pmid: 22177570].
51 Vanner S, Hookey LC. Timing and frequency of bowel activity in patients ingesting sodium picosulphate/magnesium citrate and adjuvant bisacodyl for colon cleansing before colonoscopy. Can J Gastroenterol. 2011;25(12):663-6. [pmid: 22175056].
52 Varughese S, Kumar AR, George A, Castro FJ. Morning-only one-gallon polyethylene glycol improves bowel cleansing for afternoon colonoscopies: a randomized endoscopist-blinded prospective study. Am J Gastroenterol. 2010;105(11):2368-74. [pmid: 20606677].
53 Voiosu T, Ratiu I, Voiosu A, Iordache T, Schipor A, Baicus C, et al. Time for individualized colonoscopy bowel-prep regimens? A randomized controlled trial comparing sodium picosulphate and magnesium citrate versus 4-liter split-dose polyethylene glycol. J Gastrointestin Liver Dis. 2013;22(2):129-34. [pmid: 23799210].
54 Cooper GS, Kou TD, Rex DK. Complications following colonoscopy with anesthesia assistance. JAMA Intern Med. 2013;173:551-6. [pmid: 23478904].
55 Viiala CH, Zimmerman M, Cullen DJE, Hoffman NE. Complication rates of colonoscopy in an Australian teaching hospital environment. Intern Med J. 2003;33:355-9. [pmid: 12895166].
56 Agostoni M, Fanti L, Gemma M, Pasculli N, Beretta L, Testoni PA. Adverse events during monitored anesthesia care for GI endoscopy: an 8 –year experience. Gastrointest Endosc. 2011;74:266-75. [pmid: 21704990].
57 Lieberman DA, Williams JL, Holub JL, et al. Colonoscopy utilization and outcomes 2000 to 2011. Gastrointest Endosc. 2014;80(1):133-43. [pmid: 24565067].
58 Greenfield SM, Webster GJM, Brar AS, Ah Mun K, Beck ER, Vicary FR. Assessment of residual gastric volume and thirst in patients who drink before gastroscopy. Gut. 1996;39:360-2. [pmid: 8949637].
59 Webster GJ, Bowling TE, Greenfield SM, et al. Drinking before endoscopy: milk or water?. Gastrointest Endosc. 1997;45(5):406-8. [pmid: 9165323].
60 Maltby JR, Pytka S, Watson NC, McTaggart Cowan RA, Fick GH. Drinking 300 mL of clear fluid two hours before surgery has no effect on gastric fluid volume and pH in fasting and non-fasting obese patients. Can J Anesth. 2004;51(2):111-5. [pmid: 14766684].
61 Warner MA, Warner ME, Weber JG. Clinical significance of pulmonary aspiration during the perioperative period. Anesthesiology. 1993;78:56-82. [pmid: 8424572].
62 Sakai T, Planinsic RM, Quinlan JJ, Handley LJ, Kim T-Y, Hilmi IA. The incidence and outcome of perioperative pulmonary aspiration in a University Hospital: a 4-year retrospective analysis. Anesth Analg. 2006;103:941-7. [pmid: 17000809].
63 Wexner SD, Beck DE, Baron TH, et al. A consensus document on bowel preparation before colonoscopy: prepared by a task force from the American Society of Colon and Rectal Surgeons (ASCRS), the American Society for Gastrointestinal Endoscopy (ASGE), and the Society of American Gastrointestinal and Endoscopic Surgeons (SAGES). Gastrointest Endosc. 2006;63(7):894-909. [pmid: 16733101].
64 Corley DA, Jensen CD, Marks AR, et al. Adenoma detection rate and risk of colorectal cancer and death. N Engl J Med. 2014;370(14):1298-306. [pmid: 24693890].
65 Kaminski MF, Regula J, Kraszewska E, et al. Quality indicators for colonoscopy and the risk of interval cancer. N Engl J Med. 2010;362(19):1795-803. [pmid: 20463339].
66 Ladas SD, Karamanolis G, Ben-Soussan E. Colonic gas explosion during therapeutic colonoscopy with electrocautery. World J Gastroenterol. 2007;13(40):5295-8. [pmid: 17879396].
67 Menees SB, Kim HM, Elliott EE, Mickevicious JL, Graustein BB, Schoenfeld PS. The impact of fair colonoscopy preparation on colonoscopy use and adenoma miss rates in patients undergoing outpatient colonoscopy. Gastrointest Endosc. 2013;78:510-6. [pmid: 23642491].
68 Centers for Medicare & Medicaid Services. Physician Quality Reporting System/Analysis and Payment. Available at: http://www.cms.gov/Medicare/Quality-Initiatives-Patient-Assessment-Instruments/PQRS/AnalysisAndPayment.html. 30 December 2014.
69 Bucci C, Rotondano G, Hassan C, et al. Optimal bowel cleansing for colonoscopy: split the dose! A series of meta-analyses of controlled studies. Gastrointest Endosc. 2014;80:566-76. [pmid: 25053529].