# METHODS

## TOPIC DEVELOPMENT

This topic was nominated by Jason Dominitz, MD, MHS, National Program Director for Gastroenterology, Office of Patient Care Services. Additional stakeholders were identified to include both gastroenterology and anesthesiology: John Sum-Ping, MD, Chair, National Director, Anesthesia Service; Art Wallace, MD, PhD, Chief, Anesthesia Service, San Francisco VA Medical Center; and Deborah Fisher, MD, MHS, Chair, National VA Gastroenterology Field Advisory Committee. The key questions were formulated with input from a Technical Expert Panel (TEP) consisting of gastroenterologists and anesthesiologists.

## SEARCH STRATEGY

We searched MEDLINE (OVID) for articles published from 1990 through October 2014. Our search was designed to identify studies of any design. We limited the search to studies involving human subjects published in the English language. Search terms included the following Medical Subject Headings (MeSH): Colonoscopy, Cathartics, Polyethylene Glycols, Phosphates, and Respiratory Aspiration of Gastric Contents. The full search strategy is presented in Appendix A. We also searched reference lists of guidelines, existing reviews, and included studies and we received reference suggestions from stakeholders and TEP members.

## STUDY SELECTION

Abstracts of citations identified from the literature search were assessed for relevance by an investigator. We included studies of any design that reported outcomes following bowel preparation if at least one preparation was completed within 8 hours of the colonoscopy procedure. We also include population-based studies of adverse events during colonoscopy. Additional inclusion criteria were as follows:

- Study of adults
- Study of colonoscopy with moderate or deep sedation (studies related to colorectal surgery or involving general anesthesia were excluded)
- Reports outcomes of interest during colonoscopy or recovery from colonoscopy (ie, studies of aspiration during bowel preparation were excluded)

Full text reports of studies identified as potentially eligible (or indeterminate, eg, title only) were obtained for further review using the inclusion and exclusion criteria described above. Each article was independently reviewed by 2 investigators. Reasons for excluding a study at full text review were noted.

## DATA ABSTRACTION

Eligible studies were reviewed for outcomes of interest by investigators. From studies of different preparation-to-procedure or NPO intervals, study characteristics (inclusion/exclusion criteria and details about the preparation interventions or NPO status), patient characteristics, and outcomes data were abstracted onto tables by one investigator and verified by a second. Our focus was on outcomes from different preparation-to-procedure intervals and not different preparation substances.

## RISK OF BIAS ASSESSMENT

We assessed the risk of bias of randomized controlled trials (RCTs) and controlled clinical trials (CCTs) based the following criteria: allocation sequence generation, allocation concealment, blinding, completeness of outcome reporting, and selectiveness of outcome reporting – a modification of the Cochrane approach to determining risk of bias.11 For observational studies we identified the following criteria and evaluated risk of bias for each study:

1. Study design (prospective vs retrospective)
2. Population (consecutive or not)
3. Analysis of findings
  a. Was the method for handling missing data reported and appropriate?
  b. Were the characteristics the different NPO groups similar?

Individual studies were rated as low, moderate, or high risk of bias. Low risk of bias RCTs had adequate allocation sequence generation and allocation concealment, blinding, and few patients with incomplete data. Low risk of bias observational studies were prospective, enrolled consecutive patients, had appropriate methods for handling missing data (or no missing data), and characteristics of the NPO groups were similar.

## DATA SYNTHESIS

We described and qualitatively compared the patient characteristics, study characteristics, intervention timing, and findings of included studies. Due to variation in the preparation-to-procedure interval and/or NPO status across studies and different systems used to report outcomes, we summarized most outcomes narratively.

## RATING THE BODY OF EVIDENCE

We rated the overall strength of the body of evidence for our primary and secondary outcomes using the method reported by Owens et al.12 Separate ratings were generated for RCTs/CCTs and observational studies.

## PEER REVIEW

A draft version of this report was reviewed by clinical content experts and clinical leadership. Their comments and our responses are presented in Appendix B and the report has been modified as needed.