# INTRODUCTION

Fourteen million colonoscopies are performed annually in the United States for screening, diagnosis, surveillance, and treatment of numerous colonic conditions. Colonoscopies require bowel preparation for cleansing to sufficiently visualize the colon lining and maximize quality and safety. However, inadequate preparation occurs in approximately 25% of colonoscopies, leading to cancellations, rescheduling, difficulty in detecting colonic polyps or other pathology,1,2 poor patient adherence, as well as longer procedure time. Increased financial and opportunity costs and patient dissatisfaction result.3

To optimize colon lining visualization, patients are advised to divide the bowel preparation regimen over two sessions (known as “split-dose preparation”): 1) the evening prior to the colonoscopy (PM dose) and 2) the morning of the colonoscopy (AM dose); the latter taken ideally within 2-6 hours of the planned procedure.4-7 In addition, some level of sedation (typically moderate or deep) is used in almost all colonoscopies to facilitate patient comfort and procedure quality.8,9

For both moderate and deep sedation there is significant variation among anesthesia providers as to the acceptable timing of NPO (“nothing by mouth”) including how many hours prior to the planned procedure the last bowel preparation dose can be taken in order to minimize anesthesia risk (primarily aspiration). Practice guidelines from the American Society of Anesthesiologists Committee on Standards and Practice Parameters for preoperative fasting for healthy patients undergoing elective procedures suggest the following minimum fasting periods with the goal of minimizing anesthesia-related risks (primarily aspiration): 2 hours for clear liquids (eg, water, fruit juice without pulp, carbonated beverages, clear tea, and black coffee), 6 hours for non-human milk, and 6 hours for a light meal (ie, toast and clear liquids).10 The guideline authors note that published clinical evidence is insufficient to clearly define a relationship between NPO status and risk of emesis/reflux or pulmonary aspiration. Furthermore, it is unclear how different bowel preparation agents would be classified (clear liquids or not), how the potential toxicity of bowel preparation agents might impact anesthesia-related risks, and how the volume of bowel preparation agent consumed might differ from the volume of liquids considered acceptable in the guidelines.

An optimal bowel preparation and NPO status seeks to balance the need for optimal colonic preparation, patient convenience, and scheduling efficiency (typically a shorter NPO window status) with anesthesia safety concerns for an elective procedure (typically a longer NPO status). Furthermore, performing procedures with moderate or deep sedation requires development of and adherence to local and/or national policy measures that cross multiple procedures and physician specialties. These policies include recommendations regarding NPO status. Failure to adhere to NPO status can result in cancellation or rescheduling of procedures or poor procedure preparation. This can lead to reduced procedure quality, resource efficiency, patient satisfaction, and adherence.

The purpose of this report was to review the evidence on the relationship between timing of NPO and the incidence of aspiration and other anesthesia-related harms during elective colonoscopy as well as colonoscopy rescheduling. In addition, we also reviewed the evidence on the benefits and harms of variable timing of NPO status on colonoscopy outcomes including colonoscopy quality measures, rescheduling, resource use, and patient satisfaction. The review may be used to guide policy within the VA. With input from stakeholders and TEP members, we developed the following Key Questions:

Key Question 1. Does the incidence of aspiration and other anesthesia-related harms for colonoscopy vary by NPO status or bowel prep timing (eg, > 6 hours, 2-6 hours, < 4 hours, and < 2 hours)? Does the incidence of anesthesia-related harms by NPO status vary by: a) patient characteristics (age, race, sex, obesity, comorbidities) or b) sedation (moderate, deep)?

Key Question 2. What is the effect of variable timing of bowel prep and NPO status on the quality of the bowel preparation, diagnostic yield, and colonoscopy procedural quality indicators (eg, completion rates, adenoma detection rate, total procedure time, cecal intubation time and withdrawal time)?

Key Question 3. What is the effect of NPO status prior to colonoscopy on resource use (eg, costs, unused procedure slots, delays in rescheduling, delays in diagnosis, increased volume of procedures, scheduler and nursing time associated with cancelled or delayed procedures)?

Key Question 4. What is the effect of bowel preparation and NPO status prior to colonoscopy on patient adherence to bowel preparation, colonoscopy, and/or rescheduled colonoscopy, and satisfaction with bowel preparation and/or colonoscopy?

We defined the following Population, Intervention, Comparator, Outcomes, Timing, and Setting (PICOTS) for the review:

Population: Adults undergoing bowel preparation and elective colonoscopy with moderate or deep sedation

Intervention(s): NPO status 2-4 hours (liquids and bowel preparation allowed up to 2 hours prior to procedure)

Comparator(s): Alternative timing of NPO

Outcome(s): (NOTE: limited to findings according to NPO status prior to colonoscopy)

- Co-primary outcomes: aspiration, rescheduled colonoscopies
- Secondary outcomes: adverse events (including bowel perforation and other anesthesia-related harms), diagnostic yield, completion rate, adenoma detection rate, false negative colonoscopies
- Intermediate outcomes: quality of bowel preparation, hospitalizations, costs, total procedure time, cecal intubation time, withdrawal time, unused procedure slots, delays in rescheduling, delays in diagnosis, increased volume of procedures, scheduler and nursing time, patient adherence, patient satisfaction, volume of gastric contents, pH of gastric contents

Timing: Start of sedation for colonoscopy to completion of sedation for colonoscopy

Setting: Inpatient or outpatient clinics