# STRENGTH OF EVIDENCE

Outcome Category | Outcome (# of Studies Reporting) | Results, Shorter NPO status vs Longer NPO status | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence
Primary | Aspiration, RCTs (3) | Three moderate sized trials (n=672)^a^ reported no aspiration events or no major complications related to sedation | moderate | consistent | direct | imprecise | Low
Primary | Aspiration, Obs. (2) | Two studies (n=1,646), one large and one moderately sized, reported no episodes of aspiration were observed | moderate | consistent | direct | imprecise | Insufficient
Primary | Rescheduled colonoscopies (1) | One moderate sized RCT reported fewer rescheduled colonoscopies with shorter NPO status | moderate | unknown | direct | imprecise | Insufficient
Secondary | Completion rate, RCTs (6) | Pooled results from 5 trials^a,b^ (n=1,795) found no difference between NPO status groups (RR 1.00 [95%CI 0.98, 1.01]) | moderate | consistent | direct | precise | Moderate
Secondary | Completion rate, Obs. (1) | One large retrospective study (n=5175) reported a greater completion rate with a shorter NPO status (OR 1.35 [95%CI 1.03, 1.77]) | high | unknown | direct | precise | Insufficient
Secondary | Adenoma detection rate, RCTs (1) | A single small trial (n=136)^a^ found no difference between NPO status groups | moderate | unknown | direct | imprecise | Insufficient
Secondary | Adenoma detection rate, Obs. (3) | Pooled results from 3 studies (n=8,481) found improved adenoma detection rates with a shorter NPO status (OR 1.25 [95%CI 1.13, 1.39]) | moderate | consistent | direct | precise | Low
Secondary | Diagnostic yield, RCTs (2) | Two moderate sized trials^a,b^ (n=254) reported inconsistent results in diagnostic yield of all polyps or lesions | moderate | inconsistent | direct | imprecise | Insufficient
Secondary | Bowel perforation, RCT (1) | A single moderate sized trial (n=250) reported no documented complications of perforation | moderate | unknown | direct | imprecise | Insufficient
Secondary | False negative colonoscopy (0) | No eligible studies | | | | | Insufficient

Obs. = observational studies; RCTs = randomized controlled trials; OR = odds ratio; RR = risk ratio

a One additional RCT (n=125) (Matro 2010)44 of morning-only versus evening before/morning of colonoscopy bowel preparation (all patients NPO for 4 hours with clear liquids allowed until 2.5 hours before colonoscopy) reported one aspiration event requiring 24 hour hospitalization for observations, no significant difference in completion rate, and significantly better adenoma detection rate and diagnostic yield in the morning-only preparation group.

b One study (Chiu 2006)20 was of patients getting follow-up colonoscopy