# EVIDENCE TABLES

Table 1 Study Characteristics

Table 2 Primary Outcomes

Table 3 Procedural Outcomes

Table 4 Time and Patient Outcomes

Table 5 Hospitalizations, Costs, and Adverse Events

Table 6 Gastric Contents Outcomes