# PEER REVIEW COMMENTS/AUTHOR RESPONSES

Are the objectives, scope, and methods for this review clearly described?
Yes | Thank you
Yes | Thank you
Yes | Thank you
Yes | Thank you
Yes | Thank you
Yes | Thank you
Yes | Thank you
Yes | Thank you
Is there any indication of bias in our synthesis of the evidence?
No | Thank you
No | Thank you
No | Thank you
No | Thank you
No | Thank you
No | Thank you
No | Thank you
No | Thank you
Are there any published or unpublished studies that we may have overlooked?
Yes - Diagnostic and Therapeutic Endoscopy published online July 14, 2008 (see comments below, and also attachment) Complications Following Colonoscopy With Anesthesia Assistance: A Population-Based Analysis FREE Gregory S. Cooper, MD; Tzuyung D. Kou, PhD; Douglas K. Rex, MD | Thank you for the suggestions. The first article is Schanz 2008. We have reviewed this article and would not include it because all three groups completed the prep regimen by 7 am for an afternoon colonoscopy. The article does not report aspiration or other adverse events associated with the colonoscopy procedure. The article is a comparison of prep agents, not timing. The second article suggested is Cooper 2013 which we have already included.
No
No
No
No
No
No
Yes - Though it seems reasonable on the face of it to restrict the review only to papers that compare different durations of NPO status, one could make an argument for inclusion of papers that examine the impact of an inadequate bowel preparation on colonoscopic findings. Though this could be considered indirect evidence, there is direct evidence that longer NPO status is associated with lower quality bowel preparation. Therefore, I believe that many key references may have been missed, especially concerning the impact of a poor bowel preparation on neoplasia miss rates. For example: 1) Froehlich F, Wietlisbach V, Gonvers JJ, et al. Impact of colonic cleansing on quality and diagnostic yield of colonoscopy: the European Panel of Appropriateness of Gastrointestinal Endoscopy European multicenter study. Gastrointest Endosc 2005;61:378–384. 2) Harewood GC1, Sharma VK, de Garmo P. Impact of colonoscopy preparation quality on detection of suspected colonic neoplasia. Gastrointest Endosc. 2003 Jul;58(1):76-9. Also, 3) Siddiqui AA1, Yang K, Spechler SJ, Cryer B, Davila R, Cipher D, Harford WV. Duration of the interval between the completion of bowel preparation and the start of colonoscopy predicts bowel-preparation quality. Gastrointest Endosc. 2009 Mar;69(3 Pt 2):700-6. doi: 10.1016/j.gie.2008.09.047. | As noted, the suggested references do not directly assess the effect of NPO status, the focus of the review. Froehlich 2005 and Harewood 2003 provide no information about NPO status. Siddiqui 2009 compared prep completed < 14 hours before colonoscopy to > 14 hours. We have modified the discussion to address the reviewer's point about indirect evidence.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report.
1. There was not any discussion regarding the risk of aspiration of the actual prep solution which was used for the bowel preps. In private practice, there is some amount of variability with the choice of preps used (sodium phosphate vs PEG) and the fact that PEG is hygroscopic, and may incite an ongoing inflammatory resp reaction once aspirated, whereas sodium phosphate may be more benign, although there does not seem to be much evidence in animal literature to support that.; 2. Diagnostic and Therapeutic Endoscopy July 14, 2008 (published online) compared sodium phosphate to PEG and found greater patient tolerability and at least equivocal conditions for colonoscopy with 2PEG prep volume deliveries. For difficult, non-compliant patients, this may be a good option for the VA population, since this is a much lower volume fluid, and provided at least as good scoping conditions for most endoscopists (it was a double-blinded study).; 3. In reading the actual JAMA article on complications from colonoscopy (JAMA Intern Med. 2013;173(7):551-556. doi:10.1001/jamainternmed.2013.2908.), the authors did identify some possible origins of the 173 occurrences of aspiration, including a deeper plane of anesthesia with anesthesia providers, and higher patient morbidity, which may also affect prep potential, going along with patient compliance with prep instructions and ability to complete the volume load prior to the scope. | 1. Discussion of individual prep agents and aspiration during bowel preparation were outside the scope of our review.; 2. Schanz 2008. As noted above, this is a comparison of prep agents and not timing. The focus of our review is a comparison of NPO status prior to colonoscopy.; 3. We would refrain from suggesting certain populations may be better candidates for shorter NPO based on anesthesia risk, since we find such little evidence to support risk overall with shorter NPO.
My answer to the last boiler-plate Q should be “I don't know”. Additionally:; 1. Only moderate and deep sedation are mentioned as far as anesthesia methods are concerned. In fact - most of anesthestics delivered by anesthesia teams for colonoscopies are TIVA (total intravenous anesthesia), i.e. general anesthesia (GA) (be it - without airway instrumentation). Per ASA document from 2011, the definition of GA is:; “General Anesthesia is a drug-induced loss of consciousness during which patients are not arousable, even by painful stimulation. The ability to independently maintain ventilatory function is often impaired. Patients often require assistance in maintaining a patent airway, and positive pressure ventilation may be required because of depressed spontaneous ventilation or drug-induced depression of neuromuscular function. Cardiovascular function may be impaired.”; Since the goal of our intervention is to have an insensate/ amnestic and IMMOBILE patient (i.e. not responding with movement to painful stimulation) - what we do easily satisfies the definition of GA (and we code it locally as such).; 2. Page 4, lines 26-29: what is the meaning of the statement “… two (studies) reported aspiration with no episodes”?; 3. Page 8, lines 13-19: I did not see my name among the stakeholders. As such I understand that my input into this project is completed.; 4. I read very carefully the “executive summary” and speed-read the detailed report. It is exhaustive and well executed. | 1. The key questions, developed with input from stakeholders and technical expert panel members, focused on moderate or deep sedation. We could only comment on the level of sedation as reported (or often not reported) in the individual studies.; 2. Two studies reported that they were specifically monitoring patients for aspiration events but did not observe any events. We have attempted to clarify this statement.; 3. That is correct – the stakeholders nominated the topic and may use the findings of the review to guide VA policy. As with a journal, peer reviewers do not have an ongoing connection to the topic.; 4. Thank you.
1. Please note that the four studies that addressed aspiration and sedation related complications did not include those with significant comorbidities. This is a key theme that needs to be emphasized. Subjects that may be at a theoretical risk for aspiration are not necessarily included in the studies addressing the efficacy of split dose preps.; 2. Another important issue is the definition of aspiration and how it would be diagnosed. Clearly one could theorize that a transient episode of hypoxemia during the colonoscopy may in and of itself the related to an aspiration episode. However without radiographic evidence or clinical suspicion this would be undetected.; 3. In the studies addressing gastric volume and acidity, please ensure that potential confounders such as the concomitant use of anti-secretary agents, antispasmodics or narcotic analgesics have been included in the methodology.; 4. We still do not know whether deeper levels of sedation do indeed impart an increased risk for aspiration. According to the ASA Continuum of Sedation, we would expect this to be the case.; 5. Additionally, all cases that are performed under anesthesia assistance, please comment as to whether elective endotracheal intubation was performed. This would perhaps, lead to confounding by protecting the airway as opposed to MAC without ET intubation.; All of this needs to be discussed in the Research Gaps/Future Research section | 1. This was noted in the Limitations section of the full report. We have also added a statement to the key findings in the Executive Summary.; 2. Thank you – we have added a statement addressing this limitation in the Limitations section. We also updated the discussion on aspiration definitions and implications. Most clinicians would agree that aspiration needs to be a clinically significant event. Having said that, we were limited by the definition used by individual studies.; 3. One of the studies reporting gastric volume did not report on the potential confounders listed. The other reported only that patients taking metoclopramide without proven gastroparesis were not excluded.; 4. Risk of aspiration appears greater with deeper sedation, but we did not find enough studies to distinguish the harms of moderate versus deeper sedation prior to colonoscopy in relation to NPO. We have added this concern to the Research Gaps/Future Research section.; 5. We provided information about sedation as reported in the published studies. Unfortunately, few details were provided. Furthermore, if the overall risk of aspiration is low, it would not be helpful to split it between anesthesia with or without endotracheal intubation.; We have modified the Research Gaps/Future Research to address these concerns.
It would been better if moderate sedation, deep sedation and general anesthesia are reviewed separately. There is mention that aspiration rate is higher with deep sedation compare to moderate sedation. Would the rate be even higher with general anesthesia and how would the rate change if the patient was intubated versus no intubation. The other comment is that there is not enough research to answer the questions asked. | As noted in the review, only 26 of 40 included studies reported on use of sedation during colonoscopy and few details were provided. We agree that more research is needed.
The review is well written and comes to well formulated and reasonable conclusions based on the evidence. I would make a few minor changes. The most fundamental is the concept of low risk. To an anesthesiologist 0.1% risk of aspiration is not low risk. That is a significant risk. Page 4 Line 24: I would not say “the risk of aspiration during colonoscopy is very low (1 in 1000 or less). If the risk is 0.1%, that is a high risk to an anesthesiologist. The risk of aspiration during general anesthesia for C-Section without intubation is listed as 1:200. That risk is considered, extremely high. The risk for general anesthesia is quoted as 1:20,000. So, 1:1000 is high. Page 5 Line26 I would not say “Aspiration incidence during colonoscopy with moderate or deep sedation is very low. 0.1% is a high risk to an anesthesiologist. Page 6 Line 39. You need to include a statement about the contents and volume of colon prep solutions. Colon prep solutions contain ethylene glycol which is toxic to the lung. Colon prep solutions may be transparent but would not be considered “clear liquids”. Moreover, the volume, 1 liter, is more than what is standard in NPO guidelines. Page 6 Line 16 If colon preps are inadequate 25% of the time, the efforts of GI docs to understand and correct that causes of failure: compliance, volume, diet may be more fruitful than merely having the prep closer to the time of anesthesia. Page 19 Paragraph 30-38. This paragraph isn't clear enough. There are two very separate issues. What is the time for NPO for clear liquids (water, clear juice) and what is the time for completing bowel preparations? The liquids in bowel prep solutions are very different from water. They have ethylene glycol. This paragraph needs to be in two parts. Time for NPO for clear liquids (water, clear juice). Then there needs to be a separate paragraph for Time for NPO for bowel preparation solutions. The issues are fundamentally separate to an anesthesiologist. Aspirating water is different from aspirating a liter of ethylene glycol containing salt water. Page 20 line 9: 8 hours versus 1-7 isn't very helpful. The range of 1-7 is too wide. Page25 Line 13 1:1000 is not “very low”. To an anesthesiologist, 1:1000 is a serious problem. Page 25 Line 24 The granularity of your time scale is too coarse. 1-6 hours versus 8 is not very helpful. How about 0-2, 2-4, 4-6? Is there a difference in 0-2, 2-4, 4-6? Page 25 Line 19 An absence of reported complications does not imply an absence of complications. I am suspicious when there are no events reported. No hospitalizations after a procedure is suspicious. Page 28 Line 34 “Many studies excluded patients with serous comorbidities. “ This sentence is critical to applicability. The VA patients have a high risk population with higher ages and many, many comorbidities. Page 29 Paragraph 11-31 Yes. Very well stated. Page 29 Line 35 An aspiration risk of 0.1% is NOT very low. 1:1000 is a big deal to an anesthesiologist. | Thank you. In general a 0.1% risk of an event, where the clinical consequences are not clear, would be regarded as low. Page 4. See above Page 5. See above Page 6. We have added information about contents and volume. Page 6. We have included the need to better understand patient compliance in our Research Gaps/Future Research section. Page 19. This section has been rearranged for clarity. No study reported on differences in quality of preparation between water up to the time of procedure vs no water. The studies that allowed liquids up to the time of procedure did so for all patients. Page 20. Few studies provided exact times between completion of preparation and procedure. We are only able to be as precise as the reported information. Page 25. See above Page 25. There were few comparisons between 0-2, 2-4, etc. so we are comfortable with this statement as written. Page 25. We have modified this statement to clarify that few studies specified adverse events as an outcome of interest. Page 28. As noted above, we have added this statement to the key findings. Page 29. Thank you. Page 29. See above
This was a very high quality review. I have few comments on the methodology. Unfortunately, the evidence base itself was insufficient to enable a meaningful conclusion regarding the key questions posed. My comments are mostly minor: Page 4 “Of 16 studies with NPO duration prior to colonoscopy (either bowel preparation or liquids) as low as 0 to 2 hours, 2 reported aspiration with no episodes.” – No episodes of what? Reported no episodes or did aspiration events not occur? Page 4 “Strength of evidence was insufficient for our primary outcomes of aspiration” – Does this mean the strength of evidence was insufficient for the entire meta-analysis or only for this one key question? “ and rescheduled colonoscopy.” – Was the primary outcome rescheduling? Were there multiple primary outcomes? There is some confusion here between key questions (of which there can be many) and primary outcomes (of which there should only be one) Page 5 – Conclusion- This is very well written and very clear Page 6 Lines 35-37 – these are important since they define what current standards of practice are for NPO. Later this will factor in when reviewing the literature since few of the studies examined NPO status outside of these standard windows. Thus, few studies contributed to any new knowledge on this topic. Page 9 Line 26 – What scale or system was used to assess risk of bias? Please also specify at this point in the report what constitutes low, moderate or high risk of bias. Also, I applaud the investigators for not using the GRADE system. There is an increasing trend for evidence-synthesizing bodies to use GRADE –However, GRADE is very subjective and not an optimal system | Thank you. Page 4. We have clarified this statement. Page 4. Strength of evidence is evaluated for key outcomes. For aspiration and for rescheduled colonoscopies, our primary outcomes of interest, we found insufficient evidence. We have separated this into 2 bullet points to clarify. Although “primary” implies only one, we chose to designate a harm (aspiration) and a resource use (rescheduled colonoscopy) outcome as the key outcomes for the review based on input from stakeholders and Technical Expert Panel members. Page 5. Thank you Page 6. As noted, the guideline authors acknowledge that there is insufficient clinical evidence. Page 9. For RCTs we used a modification of the Cochrane approach. For observational studies, we used a 3 criteria system that we developed. We have added information about what we considered low, moderate, or high risk of bias.
1. Page 11, Table 1: There appear to be errors in the row labels. Specifically, the age values appear to be the “range of means” not the actual range of ages. Also, the Location percentages seem to be incorrectly labeled.; 2. There seems to be an important gap in the analysis of the evidence with respect to the impact of an inadequate bowel preparation on patient outcomes. The authors do a very nice job reviewing the direct evidence linking NPO status with bowel preparation quality. However, while there may be limited direct evidence on the impact of NPO status on downstream patient outcomes, such as adenoma detection rate (ADR) or interval cancers, there is considerable evidence on the impact of an inadequate bowel preparation on these important outcomes. Recent evidence has linked the ADR to interval colorectal cancer incidence and mortality (Corley NEJM 2014). Since longer NPO status results in lower quality bowel preparation, and other studies have documented that lower quality bowel preparation is associated with lower rates of adenoma or polyp detection, then it would seem that this would be indirect evidence of lower adenoma detection with longer NPO status. This would then raise concern that longer NPO status will result in increased risk of interval cancer incidence and mortality. The risk of cancer in a VA screening colonoscopy population is between 0.5% and 1%. Among FOBT/FIT positive patients, it is as high as 5%. The lifetime risk of colorectal cancer is around 7% and it is estimated that around 5% of all cancers are now interval cancers. Most of these interval cancers are believe to be due to missed lesions during colonoscopy. Therefore, the impact of poor bowel preparation on true patient outcomes is more than a hypothetical concern.; 3. Page 26, line 14: The study showing higher aspiration incidence associated with deep sedation may be due to confounding by indication (i.e. patients at higher risk for aspiration may have anesthesia assistance brought in to reduce the risk). Endoscopists chose to have anesthesia assistance for any of a number of reasons, including significant comorbidity.; 4. Page 27, line 39: The Discussion on resource implications seems incomplete. Clearly if a longer NPO status leads to lower quality bowel preparation, there will be important resource implications. Current guidelines call for repeating the exam within 1 year (Johnson et al. USMSTF Guidelines. Gastro 2014). In many cases, the patient is asked to ingest additional bowel preparation and return the following day. The paper by Rex et al. discusses the cost of inadequate bowel preparation. Within the VA, there are many facilities that lack adequate capacity for providing colonoscopy to the Veterans who need it and, therefore, they send the Veterans to the community at considerable expense. Besides the direct financial implications, there are also direct and indirect patient costs. Moreover, some Veterans decline to return for a follow-up examination, increasing the risk of missed pathology (and subsequent increased risk of morbidity and mortality). Another key related issue is that the variable policies of individual anesthesiologists with respect to NPO status leads to canceled procedures. It is common practice at my facility for anesthesiologists to cancel a colonoscopy on the day of the procedure because the patient ingested bowel preparation <6 hours before the procedure even when some of their colleagues have a 2 hour NPO rule. This variability has resulted in our nurses advising all patients to ingest their preparation the night before and to be NPO for 6 hours. Therefore, our anesthesia cases frequently have a poor quality preparation and need to return for a repeat procedure. This exposes the Veteran to increased risk from repeat procedures and repeat sedation, in addition to the inconvenience and cost. Despite the lack of studies on this issue, these issues are commonplace in the VA and merit discussion.; 5. Page 27, line 42: It seems strange to hypothesize that a shorter NPO status might be more difficult to tolerate or adhere to when there are published meta-analyses that demonstrate that patients generally prefer a split-dose prep which generally requires a shorter NPO status. Which is even stated by the authors at line 52.; 6. Page 28: Applicability Section: It is interesting that this informal survey was included in the report. There is no doubt that some patients will have an aspiration event during sedation. But there are two major issues with presenting this information. First, related to risk: what evidence is there that a 2 hour NPO status would increase the risk of aspiration compared to 4 or 6 hours? The data presented from the EGD studies shows that there is no difference in gastric contents between shorter and longer NPO status. Since liquids empty very rapidly, it is unlikely that there is a clinically significant difference. Second, there is no consideration of the benefits of a shorter NPO status. Clearly, anesthesiologists focus on trying to reduce the risk of sedation-related complications. However, it is the responsibility of the care team (including the endoscopy AND the anesthesiologist) to consider both the risks and benefits of the procedure. If the colonoscopy has an inadequate bowel preparation, then there is risk of missed neoplasia AND risk of sedation for an inadequate examination. The authors should take a step back and discuss the overall risks and benefits. I suspect a survey of gastroenterologists will yield anecdotal reports of poor bowel preparation, interval cancers and patients who have cases canceled by anesthesiologists and then never show for their repeat exam. What value is added by including this section other than to document that anesthesiologists don't follow their own professional society guidelines? This variability leads to endoscopy units being held hostage by the anesthesia providers.; 7. Page 29: Research Gaps: While it would be nice to have high quality evidence to answer all questions in clinical practice, the reality is that this is unlikely to happen. Given that the current standard of care is to use split-dose bowel preparation for all colonoscopy, one might question the ethics of a randomized study of 2 hour vs. 6 hour NPO status. The current European guidelines state that the bowel preparation should be finished no more than 4 hours before the procedure begins. The USMSTF guidelines state that the last dose of preparation (typically 1-2 liters) should begin no more than 4-6 hours prior to the procedure (essentially finished 2-4 hours before the procedure start time). Therefore, any study that requires completing the preparation more than 6 hours before the procedure is intentionally asking patients to expose themselves to a greater risk of a poor bowel preparation. As noted by the authors, there is no evidence of harm from a shorter NPO status. Therefore, it is questionable whether an IRB would actually approve such a study. Even if it was ethical to do such a study, the low risk of aspiration would suggest that a study would need tens of thousands of subjects in each treatment arm. Perhaps the authors should include an estimated sample size for a randomized study (e.g. to show a 30% increase in aspiration risk, a study would require X subjects in each arm). There are some patients who decline a split-dose bowel preparation and have a >6 hour NPO status. However, they are not randomly selected. This raises concern about bias in observational studies in an era of split-dose preparation.; 8. As noted by the anesthesiologist survey results, there is variable practice within the VA. As noted by the authors, there is no evidence that longer NPO status increases safety for colonoscopy. Can the authors shed any light on why the anesthesiologists believe that more than 2 hours is required despite the ASA recommendation for 2 hours for clear liquids? | 1. The row labels have been corrected; 2. The Discussion section has been modified to address the indirect evidence.; 3. We have modified this statement.; 4. We have modified this paragraph.; 5. See above – we have modified this paragraph.; 6. We have modified the reporting of the survey results.; 7. The Research Gaps/Future Research section has been modified.; 8. We have modified this paragraph.