# SEARCH STRATEGY

Database: Ovid MEDLINE(R)

-------------------------------------------------------------------------------

1. colonoscopy/
2. colonic.ti,ab.
3. (endoscop$ and (colon$ or rect$)).ti,ab.
4. or/1-3
5. cathartics/ or polyethylene glycols/ or phosphates/ or laxatives/ or senna extract/ or bisacodyl/ or cascara/ or enema/ or administration, oral/
6. (prepara$ or enema$ or cathart$ or (polyethylene adj glycol$) or phosphat$ or laxativ$ or (senna adj extract$) or bisacodyl or cascara or PEG or miralax or golytely or nulytely or halflytely or fleet or dulcolax or pico selax or bowel prep$ or bowel purgative or oral or liquid).mp.
7. 5 or 6
8. respiratory aspiration of gastric contents/ or respiratory aspiration/ or pneumonia, aspiration/ or dyspnea/ or vomiting/
9. (emesis or vomit$ or reflux or bronchoaspirat$ or aspirat$ or quality or detection).ti,ab.
10. 8 or 9
11. 4 and 7 and 10
12. limit 11 to yr=”1990 -Current”
13. limit 12 to English language
14. limit 13 to humans
15. limit 14 to (“all infant (birth to 23 months)” or “all child (0 to 18 years)” or “newborn infant (birth to 1 month)” or “infant (1 to 23 months)” or “preschool child (2 to 5 years)” or “child (6 to 12 years)” or “adolescent (13 to 18 years)”)
16. limit 14 to (“all adult (19 plus years)” or “young adult (19 to 24 years)” or “adult (19 to 44 years)” or “young adult and adult (19-24 and 19-44)” or “middle age (45 to 64 years)” or “middle aged (45 plus years)” or “all aged (65 and over)” or “aged (80 and over)”)
17. 14 not 15
18. 16 or 17