# SUMMARY AND DISCUSSION

The demand for mental health services in VHA is increasing, with depressive disorders, anxiety disorders, and PTSD among the most common diagnoses. Yet, there are important barriers to in-person, evidence-based therapy, including stigma associated with mental healthcare and logistical barriers such as transportation challenges, time constraints, and limited available appointments. The VA/DoD have begun to invest in web-based self-help programs such as cCBT to help overcome these barriers; for example, people can participate when convenient for them from home. Thus, this evidence review was commissioned to inform development of such programs.

We identified 47 randomized controlled trials involving 7270 patients that were relevant to our study questions. The most studied conditions were depressive disorders, generalized anxiety disorder, and panic disorder. Participants in these included trials were typically mid-life adults with moderate symptom severity. The cCBT interventions were delivered most often through web-based applications with at least a limited degree of remote therapist support. All studies reported short-term effects on symptom severity, with a subset of studies also reporting longer term effects on HRQOL. When meta-analysis was possible, treatment effects were summarized using the SMD. Adverse effects were not reported systematically in the included studies. Next, we summarize our findings and the overall strength of evidence (SOE) by KQ.

## SUMMARY OF EVIDENCE BY KEY QUESTION

### KQ 1 Effects of cCBT Interventions Compared With Controls

We found at least moderate SOE that cCBT interventions improved symptoms to a greater degree than control conditions (usual care, waitlist, or attention controls) for depressive symptoms, major depressive disorder, generalized anxiety disorder, and panic disorder (Table 11). For the latter three conditions, the effects measured at end of treatment were large. For PTSD and anxiety symptoms, however, there were few trials, and our confidence in the estimate of treatment effect was low. Patterns were similar for effects on HRQOL.

Table 11 Summary of the strength of evidence for KQ 1: cCBT compared with control at end of treatment by disorder

Outcome | Strength of Evidence Domains | | | | Effect Estimate (95% CI)^a^ | SOE
Outcome | Number of Studies (Patients) | Study Design/Risk of Bias | Consistency Directness | Precision Publication Bias | Effect Estimate (95% CI)^a^ | SOE
Adults with depressive symptoms
Symptom severity | 13 (3010) | RCT/Moderate | Inconsistent Direct | Precise None detected | SMD = −0.38 (−0.50 to −0.27 ) | Moderate
HRQOL | 4 (1269) | RCT/Moderate | Consistent Direct | Precise None detected | SMD = 0.26 (0.11 to 0.41) | Moderate
Adults with major depressive disorder or dysthymia
Symptom severity | 11 (931) | RCT/Moderate | Consistent Direct | Precise None detected | SMD = −0.84 (−1.01 to −0.67) | High
HRQOL | 8 (941) | RCT/Moderate | Consistent Direct | Precise None detected | SMD = 0.37 (0.22 to 0.52) | High
Adults with generalized anxiety disorder
Symptom severity | 4 (321) | RCT/Low | Consistent Direct | Imprecise None detected | SMD = −0.94 (−1.34 to −0.54) | Moderate
HRQOL | 3 (176) | RCT/Moderate | Consistent Direct | Imprecise None detected | SMD = 0.57 (0.27 to 0.87) | Low
Adults with panic disorder
Symptom severity | 7 (333) | RCT/Moderate | Consistent Direct | Imprecise None detected | SMD = −1.08 (−1.45 to −0.72) | Moderate
HRQOL | 6 (250) | RCT/Moderate | Consistent Direct | Imprecise None detected | SMD = 0.49 (0.23 to 0.75) | Moderate
Adults with PTSD
Symptom severity | 2 (71) | RCT/Moderate | Consistent Direct | Imprecise None detected | No summary estimate. SMD range from −0.42 to −0.46 | Low
HRQOL | 1 (40) | RCT/Moderate | NA Direct | Imprecise None detected | No summary estimate. SMD = 0.60 (−0.04 to 1.23) from one study | Insufficient
Adults with anxiety symptoms
Symptom severity | 2 (132) | RCT/High | Consistent Direct | Imprecise None detected | No summary estimate. SMD range from −0.28 to −0.42 | Low
HRQOL | 0 (0) | NA | NA NA | NA NA | NA | Insufficient

a For symptom severity, a negative effect estimate favors cCBT; for health-related quality of life, a positive effect estimate favors cCBT.

Abbreviations: CI=confidence interval; HRQOL=health-related quality of life; NA=not applicable; PTSD=posttraumatic stress disorder; RCT=randomized controlled trial; SMD=standardized mean difference; SOE=strength of evidence

The literature on major depressive disorder indicates that an increase in depressive symptoms months after the end of cCBT is to be expected; however, one review found that a minority of patients (approximately 26% to 31%) relapse to significant depressive symptoms.86 For the subset of trials included in our systematic review that evaluated outcomes at 6 months or longer, treatment effects were smaller but remained statistically significant.

Adherence to treatment was highly variable with fewer than one-half of participants completing all planned treatment sessions (median 44%; range 11% to 95%). This rate of adherence is low compared with general estimates of treatment completion for major depressive disorder87 and generalized anxiety disorder,88, as well as studies using in-person CBT with Veterans.89,90 The limited adherence rates in trials, where patients are often more adherent than in typical practice, is a concern for effective implementation of cCBT.

### KQ 2 Characteristics and Effects of User Support Provided in cCBT Programs

Most of the cCBT interventions were accessed via the internet from nonclinical locations and were supported by a therapist. Approximately one-third included a peer support discussion board. The level of therapist support varied widely, ranging from minimal feedback on homework assignments via email to a full therapy session via instant messaging or a chat room format. In two studies, cCBT was used as an adjunct to face-to-face therapy, but for most interventions, cCBT was a standalone treatment. Exploratory subgroup analysis, using indirect comparisons, showed an association between higher levels of support and greater treatment effects. Two small studies directly compared different levels of therapist support and did not find a differential treatment effect.

### KQ 4 Effects of cCBT Interventions Compared With Face-to-Face Therapy

Seven studies directly compared cCBT with face-to-face therapy (Table 12). Panic disorder was the only condition with more than two studies making this comparison, and these trials showed no difference in effects on symptom severity or HRQOL (moderate SOE). Two studies, a relatively large, high-quality trial62 and a smaller, fair-quality trial,79 found no difference in treatment effects for participants with depressive symptoms (low SOE). The sample size in the single pilot study on major depressive disorder was too small to determine SOE. Therefore, we conclude the current literature is generally insufficient for making a determination about whether the efficacy of cCBT is comparable to traditional, face-to-face therapy.

Table 12 Summary of the strength of evidence for KQ 3

Outcome | Strength of Evidence Domains | | | | Effect Estimate (95% CI)^a^ | SOE
Outcome | Number of Studies (Patients) | Study Design/Risk of Bias | Consistency Directness | Precision Publication Bias | Effect Estimate (95% CI)^a^ | SOE
Adults with depressive symptoms
Symptom severity | 2 (254) | RCT/Low | Consistent Direct | Imprecise None detected | No summary estimate. SMD range (0.01 to 0.06) | Low
HRQOL | 0 (0) | NA | NA NA | NA NA | No studies | Insufficient
Adults with major depression or dysthymia
Symptom severity | 1 (26) | RCT/Moderate | NA Direct | Imprecise None detected | No summary estimate. SMD = −0.20 (−0.98 to 0.57) from one study | Insufficient
HRQOL | 0 (0) | NA | NA NA | NA NA | No studies | Insufficient
Adults with panic disorder
Symptom severity | 4 (319) | RCT/Low | Consistent Direct | Imprecise None detected | SMD = −0.07 (−0.34 to 0.21) | Moderate
HRQOL | 3 (239) | RCT/Low | Consistent Direct | Imprecise None detected | SMD = −0.07 (−0.34 to 0.21) | Moderate

a For symptom severity, a negative effect estimate favors cCBT; for health-related quality of life, a positive effect estimate favors cCBT.

Abbreviations: HRQOL=health related quality of life; NA=not applicable; RCT=randomized controlled trial; SMD=standardized mean difference; SOE=strength of evidence

## CLINICAL AND POLICY IMPLICATIONS

Computerized CBT, through the internet or computer-based applications, has the potential to overcome barriers to evidence-based therapies—particularly for patients who live long distances from trained clinicians. This mode of delivery also has the potential to address shortages in the number of trained mental health professionals and might possibly lower the cost of care. Computerized CBT is estimated to cost $50 to $550 per client episode of completed treatment. By comparison, fees for individual psychotherapy, typically range from $80 to $160 per single session in the United States. Despite this potential, however, few clinical guidelines address cCBT, including those from the VA/DoD,91 American Psychiatric Association,92 and the Canadian Network for Mood and Anxiety Treatments.93 In the United Kingdom, the National Institute for Health and Care Excellence (NICE) depression guideline recommends, “For people with persistent subthreshold depressive symptoms or mild to moderate depression, consider offering … computerised cognitive behavioural therapy.”94 Further, the guidelines state the computerized CBT be “provided via a stand-alone computer-based or web-based programme, include an explanation of the CBT model, encourage tasks between sessions, and use thought-challenging and active monitoring of behaviour, thought patterns and outcomes, be supported by a trained practitioner, who typically provides limited facilitation of the programme and reviews progress and outcome, and typically take place over 9 to 12 weeks, including follow-up.”94 NICE makes similar recommendations for generalized anxiety disorder.95 Our systematic review is consistent with these guideline recommendations. That is, cCBT programs, supported by trained practitioners, have short-term benefits for individuals with major depression, generalized anxiety disorder, panic disorder, and, to a lesser extent, people with depressive symptoms.

Although our review supports cCBT for selected conditions, a number of cautions relate to applicability to Veterans and issues of how best to implement cCBT in the VA health system. Because most of the cCBT interventions excluded participants with active suicidal ideation or severe symptoms, very little information is available on the efficacy of cCBT for managing patients in crisis. Current evidence does not support cCBT for patients in crisis or with severe illness. Also, the use of cCBT technology brings with it privacy and information security risks that must be addressed to ensure that these risks are eliminated or at least communicated to Veterans using cCBT. For treatments that use electronic messaging from hospital staff to remind patients to complete modules or to address questions, secure messaging systems will need to be integrated with the treatment. Because cCBT often utilizes web-based modules, the security of information transmitted and stored on these sites will need to be addressed.

Veterans enrolled in the VA health system are older, on average, than those in the clinical trials and have higher levels of chronic health conditions. Information on comorbid conditions was reported infrequently in the trials of cCBT. Patients with mental health conditions and severe comorbid physical or mental conditions (e.g., depressive disorder plus PTSD or diabetes) may be less responsive to treatment, or they may find that distance-based treatment is isolating, particularly when it involves briefer and fewer instances of asynchronous communication.96 Despite this caution, there is some evidence that cCBT is acceptable to older adults.97 Younger, more tech-savvy Veterans may be particularly appropriate candidates for cCBT.

In the studies we reviewed, older individuals were not included (median age 39.8, range 20 to 58), so the utility of cCBT in Veterans age 60 and older is unknown. It is also worth considering that most of the cCBT interventions reviewed required computer and internet access at home. While internet access in the Veteran population is likely to increase over time, results from the 2010 National Survey of Veterans indicated that 71 percent were using the internet,98 so cCBT is likely not an ideal choice for the minority of Veterans who do not use the internet.

Interest in undertaking cCBT could vary substantially across patients. As a consideration in implementing cCBT, some clinics might offer it as an alternative to face-to-face therapy, to be selected only by patients that prefer the accessibility of cCBT. If clinics are considering this implementation method, it would be helpful to conduct more research on the influence of treatment choice on outcomes. This could be accomplished with trial designs that randomized to choice versus no-choice conditions. Alternatively, clinics might consider using cCBT in a stepped-care model that offers cCBT as a first-line psychotherapy. In this model, patients who do not report benefit from cCBT could then be referred for face-to-face therapy. Clinics implementing cCBT also need to consider the staffing needs of these interventions. While therapist burden is expected to be reduced, at least some level of therapist involvement is reasonable to ensure that patients receive reinforcement of material presented in cCBT. Some of the studies we reviewed used technicians, as opposed to clinicians, to provide human support. While few studies have compared technicians with clinicians, those that did generally found that technicians performed well. As a result, clinics could consider nonclinician staff members to be used in resolving questions about procedural problems with the cCBT program or routine questions about treatment content. However, therapists must remain available for consultation, because there will continue to be a potential for crisis issues that demand clinical expertise.

Some cCBT programs, including Beating the Blues and FearFighter™, are included as a covered benefit by the national health services of the United Kingdom, Australia, New Zealand, and Canada.99 In the United States, Ultrasis partnered with University of Pittsburgh to form U2 Interactive to market Beating the Blues.100 The VHA will need to determine whether to make an existing program available to its patients or develop its own programs. Especially for disorders like major depressive disorder or generalized anxiety disorder, for which we found no statistically significant evidence of heterogeneity in treatment effects across studies, it is reasonable to expect that VHA researchers could develop programs that will achieve treatment outcomes similar to those observed in previous studies. For either approach, issues of privacy, including HIPAA compliance, and how to make the program available—through referral by VA clinicians or more widely to any Veteran—will require careful consideration. New programs could be tailored to a Veteran sample and could incorporate recent developments in treatment as well as be adapted for increasingly prevalent technologies such as smartphones. VHA has introduced some smartphone apps (e.g., PTSD Coach, www.ptsd.va.gov/apps/ptsdcoachonline/default.htm) that offer assessment, basic coping tools, and referral to treatment resources. The methods used to communicate and disseminate these apps to Veterans could serve as a foundation for providing cCBT, which is a more in-depth treatment modality.

Our review suggests greater effects for patients meeting criteria for full disorders and mild to moderate symptom severity. Requiring a diagnosis and clinician referral to the program could ensure more careful diagnostic evaluations and closer followup. However, this approach could partially negate some of the advantages of the cCBT format, such as anonymity and overcoming time constraints and travel barriers. If the VHA were to develop its own cCBT programs, they should utilize the approaches found in the more effective interventions and be sensitive to the user interface, which could affect engagement and treatment adherence. For major depression, our review provides support for a fairly uniform benefit from multiple cCBT interventions, suggesting that treatment benefit is derived from the general principles of CBT rather than any one specific cCBT program. In contrast, studies of patients with anxiety disorders had more variability in treatment effects, raising the possibility that effects are specific to the type of program used.

Another consideration is how much therapist support to provide with cCBT treatments. Psychotherapy models typically include the therapeutic alliance between patient and therapists as an important mechanism of achieving improved psychiatric symptoms. At this point, it is unclear to what extent a relationship with a therapist is needed to optimize cCBT treatment outcomes, but there is reason to suspect it will be an important consideration. Based on indirect comparisons, we found a relatively consistent gradient showing greater treatment effects with greater support. However, very few studies evaluated more intensive human support for some conditions, and we were unable to isolate the specific features or degree of support associated with treatment benefit. Based on current evidence, we conclude that health systems implementing cCBT should include therapist support via email or brief telephone sessions, or both. The studies we reviewed did not provide reliable estimates of the panel size that a single therapist could support, but based on the median of approximately 15 minutes devoted to each patient weekly, a therapist supporting cCBT could provide care to a substantially larger cohort than those utilizing face-to-face therapy.

Finally, the VHA should not underestimate the challenge of introducing different approaches to care delivery. Successful implementation of cCBT will likely require a carefully planned approach.

## STRENGTHS AND LIMITATIONS

Our study has a number of strengths, including a protocol-driven review, a comprehensive search, a careful quality assessment, and rigorous quantitative synthesis methods. Our report, and the literature, also has limitations. Important limitations of the literature include the few studies in conditions of high priority to the VA (e.g., PTSD), few studies with longer term outcomes, and few studies directly comparing cCBT with differing levels of therapist support, such as length of the interaction, speed of the interaction (i.e., instant messaging vs. email), and the mode of support (email vs. chat room vs. phone). To more definitively address cCBT effectiveness in patients with PTSD, anxiety symptoms, or multiple/comorbid diagnoses—as well as the association between therapist support and treatment benefit—additional carefully designed trials will be needed.

Other limitations include the choice of controls for some trials, patient recruitment through advertisement, and relatively high dropout rates in many studies. Selection of the most appropriate control in trials of psychotherapy is challenging, but waitlist controls may overestimate the treatment benefit compared with studies that use treatment as usual or attention controls. Patient recruitment through advertisements, particularly over the internet, may select patients who are more adept users of internet technology but who may not have a medical home if a crisis arises. In addition, high dropout rates, even when appropriate statistical correction is employed, may bias toward greater treatment effect. Last, we were concerned about the lack of systematic reporting of safety data.

Limitations of our review methodology include a limited ability to detect publication bias due to small numbers of studies in the meta-analyses as well as the challenge of classifying the levels of cCBT support even though we used relatively broad categories. We supplemented our statistical assessment for publication bias (using funnel plots) with a search of www.clinicaltrials.gov and did not identify a pattern of completed but unpublished studies. Although we classified studies into broad categories of support, which would act to minimize the association with treatment outcomes, our mixed-treatment effect subgroup analyses found an important association, which suggests that this approach did not obscure the association.

## RECOMMENDATIONS FOR FUTURE RESEARCH

We used the framework recommended by Robinson et al.101 to identify gaps in evidence and classify why these gaps exist. This approach considers PICOTS (population, intervention, comparator, outcomes, timing, and setting) to identify gaps and classifies them as due to (1) insufficient or imprecise information, (2) biased information, (3) inconsistency or unknown consistency, and (4) not the right information. Using this structure, we have identified gaps in evidence and propose study designs to address these gaps (Table 13). VA and other healthcare systems should consider their clinical and policy needs when deciding whether to invest in research to address gaps in evidence.

Table 13 Evidence gaps and future research needs

Evidence Gap | Reason | Type of Studies to Consider
Patients
Effects in patients with PTSD or anxiety symptoms | Insufficient information | Randomized controlled trials
Effects on access to care | Insufficient information | Observational studies to evaluate if cCBT users differ from users of traditional mental health services and changes in proportion of veterans with mental illness receiving evidence-based therapies
Identifying factors (such as severity, educational level) that predict successful treatment with cCBT | Insufficient information | Large trials, observational studies, or patient level meta-analysis
Interventions
Optimal level of therapist support | Insufficient information Exploratory analysis suggest possible differential effect | RCTs or quasi-experimental studies of limited versus more robust therapist support
Optimal mode of support delivery, i.e., phone vs. email vs. chat-room, etc. | Insufficient information | Head-to-head comparisons of mode, duration and intensity of therapist support.
Amount of therapist support. i.e., frequency and duration of contact independent of mode | Insufficient information | Head-to-head comparisons of mode, duration and intensity of therapist support.
Optimal case-load for a therapist supporting cCBT interventions | Insufficient information | Time-in-motion or related study designs
Optimal platform (e.g., web or mobile device) and interface design | Insufficient information: few studies of mobile devices; no detailed analysis of web design features | RCTs, quasi-experimental, and single case experimental designs to test novel technology. Studies should contain multiple platform comparisons including web-only, web + mobile, web on mobile, and mobile-only. Also include various mobile features such as text messaging, video messaging, and mobile applications.
Comparator
Effectiveness compared to in person treatment | Insufficient information | Trials with end or treatment and 6 to 12 month outcome assessments
Outcomes
Effects on adherence rates | Insufficient information | Trials with 6- to 12-month outcome assessments
Durability of treatment effects beyond the end of treatment | Insufficient information | Trials with 6- to 12-month outcome assessments
Uncertain effects on adverse events and patient safety | Insufficient information | Multisite observational studies; patient registries

Abbreviation: cCBT=computerized cognitive behavioral therapy; PTSD=posttraumatic stress disorder; RCT=randomized controlled trial

## CONCLUSION

We found moderate to strong evidence that cCBT is effective in improving short-term symptoms for mid-life patients with major depressive disorder, generalized anxiety disorder, and panic disorder. Treatment effects were smaller for patients with depressive symptoms. We found evidence suggesting that the level of therapist support was related to the magnitude of benefit, but additional head-to-head trials are needed to address this issue definitively. VA/DoD should consider this body of evidence when updating their clinical guidelines for depression and anxiety disorders.