# RESULTS

## LITERATURE SEARCH

The flow of articles through the literature search and screening process is illustrated in Figure 2. We identified 1552 unique citations from a combined search of MEDLINE (via PubMed, n=483), CINAHL (n=356), Embase (n=232), PsycINFO (n=168), and Cochrane (n=313) conducted from 1990 through January 4, 2013, and updated on August 30, 2013. Manual searching of included study bibliographies and review articles identified 13 additional citations for a total of 1565 citations. After applying inclusion and exclusion criteria at the title-and-abstract level, 285 full-text articles were retrieved and screened. Of these, 231 were excluded at the full-text screening stage, leaving 54 articles (representing 47 unique trials and 7 companion articles) for data abstraction.

Figure 2 Literature flow diagram

^a^ Refer to Glossary for a definition of companion articles.

Our search of www.clinicaltrials.gov on August 2, 2013, identified one relevant article missed by our literature search.39 All other articles identified were captured by the update to the literature search performed on August 30, 2013.

It was necessary to contact 24 authors for clarification of abstracted elements during the course of the data abstraction process. Twelve authors responded with the requested information.

## DESCRIPTION OF INCLUDED STUDIES

We identified 47 unique RCTs involving 7270 patients that met our inclusion criteria.39–85 Because some trials contained multiple treatment arms, there were 64 comparisons relevant to this review: 53 compared cCBT with control (KQ 1), 4 compared cCBT with different levels of therapist support (KQ 2), and 7 compared cCBT with face-to-face therapy (KQ 3).

The 47 trials targeted the following patient groups:

- Depressive symptoms (15 trials)42,44,48,49,56,58,60,62,71,72,78,79,82–84
- Major depressive disorder (11 trials)39,43,45,52,54,55,57,64,67,80,81
- Depression, anxiety, or mixed anxiety/depression (3 trials)68,70,85
- Panic disorder (10 trials)41,50,51,59,63,65,66,69,74,75
- Generalized anxiety disorder (4 trials)40,46,53,73
- PTSD (2 trials)47,61
- Anxiety symptoms (2 trials)76,77

Participants in the trials were often in the middle-aged adult range (median 39.8 years of age; range 20.7 to 58.0 years of age). Most trials specifically excluded patients currently engaged in traditional CBT and patients with suicidal ideation or concurrent substance abuse. Many studies excluded patients with severe symptoms. Psychotropic medications, usually with a restriction for a stable dose, were allowed in approximately 70 percent of the studies. cCBT interventions were almost always provided by remote web-based access and only rarely in office settings. When delivered by remote access, most studies used some degree of therapist support.

The majority of the 47 included trials were conducted outside of the United States; only one61 was conducted with U.S. military personnel or Veterans. Overall risk of bias was assessed as high in 5 studies, moderate in 27 studies, and low in 15 studies. Common methodological concerns included outcome assessment by personnel with knowledge of treatment assignment and unclear or inadequate randomization or allocation concealment procedures. All but one trial72 reported one or more measures of symptom severity, and 25 reported HRQOL at the end of treatment; 22 trials also reported symptom severity at a later followup. Outcomes were assessed between 7 and 14 weeks for end of treatment in most studies (83%) and ≥24weeks for later followup.

Detailed study characteristics for the 47 trials are in Table D-1 in Appendix D. Next, we give further details and analysis of the included studies organized by KQ.

## KEY QUESTION 1 For adults with depressive disorder, posttraumatic stress disorder, panic disorder, or generalized anxiety disorder, what are the effects of cCBT interventions compared with inactive controls?

### Key Points

- Computerized CBT was delivered primarily through the internet, and most trials (79%) utilized some form of therapist support.
- Only 47 percent of trials reported effects on HRQOL.
- Data are lacking on cCBT safety and adverse events.
- Treatment adherence was reported in 62 percent of comparisons and varied substantially across studies (median proportion completing all cCBT sessions was 49.5%, range 11% to 100%. Adherence rates were lower for patients with depressive symptoms than for other conditions.
- For patients with depressive disorders or symptoms:
  ○ Compared with control groups, trials of patients diagnosed with major depressive disorder who received cCBT generally reported large treatment effects at end of treatment (standardized mean difference [SMD] −0.82), with relatively little variability between studies, though more distal followup effects were more modest.
  ○ Trials of patients identified with depressive symptoms from self-report questionnaires, with no confirmed depression diagnosis, found only modest effects at end of treatment and followup (SMD −0.40), and treatment effects varied importantly across trials. Heterogeneity in treatment effects was explained in part by the category of cCBT support but not by the type of control group.
  ○ In trials of major depressive disorder and depressive symptoms, cCBT resulted in small to moderate improvements in HRQOL relative to control groups (SMD 0.37 and 0.26 respectively).
  ○ The type of control group did not explain variability in treatment effects.
- For patients with anxiety disorders or symptoms:
  ○ Treatment effects were large and consistent across trials of patients with generalized anxiety disorder (SMD −.94). Trials of panic disorder also had large treatment effects (SMD −1.08), but they were inconsistent across interventions. Heterogeneity in treatment effects was explained in part by the category of cCBT support.
  ○ Few trials evaluated the long-term treatment effects of cCBT interventions. The available evidence suggests that treatment effects are small at 6 months or longer.
  ○ In trials of generalized anxiety disorder and panic disorder, cCBT resulted in moderate improvements in HRQOL relative to control groups (SMD 0.57 and 0.49 respectively).
  ○ The evidence was insufficient to determine the effect of cCBT in patients with PTSD or in patients with anxiety symptoms who were not diagnosed with a specific disorder.

### Study Characteristics

We identified 43 trials involving 6960 patients and 53 comparisons that met inclusion criteria for evaluating KQ 1.^39–49,51–58,60–65,67–78,80–85^ Of these 43 trials, 11 (15 comparisons) evaluated the effects of cCBT versus control on treatment of major depressive disorder, and 14 (18 comparisons) enrolled participants who exceeded a threshold for significant depressive symptoms on a self-report questionnaire. For anxiety disorders, 4 trials (5 comparisons) targeted generalized anxiety disorder, 7 (8 comparisons) targeted panic disorder, 2 (2 comparisons) targeted PTSD, and 2 (2 comparisons) enrolled participants on the basis of exceeding a threshold of significant anxiety symptoms. Last, 3 trials (3 comparisons) targeted psychiatric disorder symptoms in a mixed group of patients with depressive and anxiety disorders.

Table 5 summarizes the patient and study characteristics of the 43 trials, including the 53 comparisons between cCBT and control. Racial background of participants was reported in only 8 trials, with the majority of participants being white, although one trial82 reported the percentage of participants who spoke English at home. We report the effects of treatment by target disorder and outcome: (1) symptom severity and HRQOL at end of treatment and (2) symptom severity at later followup. These summary estimates of treatment effect are presented as SMDs. For symptom severity, we explore heterogeneity in end-of-treatment effects, categorizing studies by the level of cCBT support and type of comparator. Other outcomes (e.g., patient satisfaction, treatment adherence) are summarized qualitatively across all studies.

Table 5 Study characteristics of cCBT interventions

Study characteristics
N trials (N patients) | 43 trials (6960 patients)
Trial location: N (%)
United States | 4 (9.3%)
Western Europe | 22 (51.2%)
Australia/New Zealand | 17 (39.5%)
Disorders: N (%)
Major depressive disorder | 11 (25.6%)
Significant depressive symptoms | 14 (32.6%)
Generalized anxiety disorder | 4 (9.3%)
Panic disorder | 7 (16.3%)
Mixed disorders | 3 (7%)
Posttraumatic stress disorder | 2 (4.7%)
Significant anxiety symptoms | 2 (4.7%)
Studies reporting ≥6 months of followup for treatment and control: N (%)
Followup data reported | 19 (44.5%)
Followup data not reported | 24 (56.5%)
Studies reporting treatment adherence at end of treatment: N (%)
Adherence reported | 27 (63%)
Adherence not reported | 16 (47%)
Patient characteristics
Age: median (range) | 41.5 (20.7 to 57.9)^a^
Sex: N patients (%)
Female | 4055 (59.7%)
Male | 2805 (40.3%)
Time of end-of-treatment outcomes assessment: N (%)^b^
6 weeks or less | 5 (11.6%)
7–9 weeks | 19 44.2%)
10–17 weeks | 19 (44.2%)
Intervention characteristics (53 total cCBT comparisons)
Level of therapist support: N (%)
No support | 15 (28.3%)
Support | 25 (47.2%)
Live support | 11 (20.7%)
Adjunct to therapy | 2 (3.8%)
Control group type: N (%)
Waitlist | 28 (65.1%)
Treatment as usual | 7 (16.3%)
Attention/information control | 8 (18.6%)

a Age represents 42 of the 43 studies because one study reported age as a range.

b One study74 reported end-of-treatment outcomes ranging from 6 to 14 weeks after baseline assessment, but this study was categorized as 7 to 9 weeks followup for this table.

### Effects of cCBT Interventions in Patients with Depressive Disorders and Symptom Thresholds

#### End-of-Treatment Outcomes

Figure 3 shows a forest plot of SMDs for all studies conducted in patients with depression. Of the 43 treatment-versus-control comparisons used in the quantitative meta-analysis, 14 trials (18 comparisons) examining patients with depressive symptoms provided end-of-treatment outcome data. In these comparisons, cCBT was associated with a small to moderate difference in depression severity (SMD −0.40; 95% CI, −0.49 to −0.31) with evidence of heterogeneity in effect sizes (Q=42.38; p=0.001; I^2^=60%).

Figure 3 Forest plot of cCBT versus control in patients with major depressive disorder or depressive symptoms

Abbreviations: CI=confidence interval; Dep Sxs=depressive symptoms; cCBT=computerized cognitive behavioral therapy; MDD=major depressive disorder; Std diff=standardized difference; Sx=symptom

Of all of the patient groups we analyzed, only the depressive symptom group and MDD group had enough studies (≥10) to conduct an analysis of potential publication bias using funnel plots (Figures 4 and 5). Visual inspection of the depressive symptoms funnel plot suggests possible publication bias, though testing was not statistically significant (Kendall’s Tau=−0.24; p=0.16). Adjustment for publication bias using Duval and Tweedie’s trim and fill method resulted in a small but still statistically significant difference for the cCBT intervention (SMD −0.33; 95% CI, −0.44 to −0.22).

Figure 4 Funnel plot of studies conducted in patients with depressive symptoms

Abbreviations: Std diff=standardized difference

Figure 5 Funnel plot of studies conducted in patients with major depressive disorder

Abbreviations: Std diff=standardized difference

Visual inspection of the MDD funnel plot was not suggestive of publication bias, and the statistical test was not significant (Kendall’s Tau=−0.36; p=0.15).

Eleven trials (15 comparisons) examining patients with major depressive disorder provided end-of-treatment outcome data. In these comparisons, cCBT was associated with a large difference in depressive symptoms compared with control groups (SMD −0.82; 95% CI, −0.98 to −0.67). There was no evidence of heterogeneity between comparisons (Q=10.33; p =.74; I^2^=0%). Treatment effects differed significantly between comparisons enrolling patients based on symptom thresholds and those confirming major depressive disorder with a diagnostic interview (Q=20.84, p<.001).

#### Subgroup Analyses

To examine treatment heterogeneity, we conducted mixed-treatment effects subgroup analyses for two prespecified factors: (1) level of cCBT support and (2) type of control group.

##### Level of cCBT Support

To examine potential influences of different levels of human support for cCBT interventions, we classified interventions into the four categories (defined in Methods) based on the level of cCBT support involved. Because treatment effects varied significantly between comparisons where participants exceeded depressive symptom thresholds and comparisons where participants were diagnosed with major depressive disorder, the influence of level of support was analyzed separately by type of sample. Figure 6 shows a forest plot of SMDs for all trials conducted in patients with depressive symptoms by level of support. A mixed-treatment effects subgroup analysis with participants enrolled on the basis of self-reported depressive symptom thresholds suggested that more intensive support resulted in stronger effects (Q (2)=6.35, p=.042). Two studies with two comparisons examining patients with depressive symptoms found that the cCBT-LS interventions reported large differences compared with control. Of these, one included weekly 10-minute phone calls with a counselor (SMD −1.08; 95% CI, −1.83 to −0.33).44 Another used live chat rooms for facilitators to present material and respond to participant questions (SMD −0.75; 95% CI, −1.01 to −0.49).42 Approximately 25 percent of the variability in treatment effect was explained by the category of cCBT support.

Figure 6 Forest plot of cCBT versus control in patients with depression symptoms by level of support

Abbreviations: CI=confidence interval; cCBT=computerized cognitive behavioral therapy; NS=no support; S=support; LS=live support; Sx=symptoms

Figure 7 shows a forest plot of SMDs for all studies involving participants with major depressive disorder. Though all types of comparisons reported relatively large effect sizes, the influence of level of support among participants with diagnosed major depressive disorder was not clear.

Figure 7 Forest plot of cCBT versus control in patients with major depressive disorder by level of support

Abbreviations: CI=confidence interval; cCBT=computerized cognitive behavioral therapy; NS=no support; S=support; LS=live support; Sx=symptoms; AT=adjunct to therapy

A mixed-treatment effects subgroup analysis did not provide evidence of differences among this group of comparisons based on level of support (Q (3)=2.67, p=0.45). However, there were limited numbers of comparisons in each category of support, and treatment effects were consistently large, so there was limited power to find any effect of level of support.

##### Type of Control Group

To examine potential influences of the type of control group selected for comparison with the cCBT group, we classified control groups into three categories (defined in Methods): waitlist, treatment as usual, and attention/information. As before, we analyzed trials of depressive symptoms separately from trials of major depressive disorder. In patients with depressive symptoms, five trials (seven comparisons) used a treatment-as-usual control, six trials (seven comparisons) used waitlist, and three trials (four comparisons) used an attention/information control. Treatment effects varied across a narrow range (SMD −0.32 to −0.48) and did not differ significantly by the type of control (p=0.50).

Analyses of the influence of type of control group were inconclusive for major depressive disorder comparisons because all but four employed waitlist control groups, and effects were consistently large in the included trials. A mixed-treatment effects subgroup analysis showed no statistically significant difference by control group type (Q (2)=2.83, p=.24).64

#### Health-Related Quality-of-Life Outcomes

Twelve trials (17 comparisons) examining patients with depressive symptoms or major depressive disorder provided end-of-treatment data for HRQOL outcomes (Figure 8). Four trials (6 comparisons) were in patients with depressive symptoms, and 8 trials (11 comparisons) were in patients with diagnosed major depressive disorder. Trials of patients with depressive symptoms found a small difference (SMD 0.26; 95% CI, 0.11 to 0.41) in favor of increased HRQOL in the cCBT group without significant heterogeneity in treatment effect (Q (5)=3.41, p=.64). Trials of patients with major depressive disorder also found a relatively small difference (SMD 0.37; 95% CI, 0.23 to 0.52) with heterogeneity analyses that were not statistically significant (Q (10)=9.98, p=.44). A mixed-treatment effects subgroup analysis found no statistically significant difference between the depressive symptom and major depressive disorder samples (Q (1)=1.04, p=.31).

Figure 8 Forest plot of cCBT versus control in patients with major depressive disorder or depressive symptoms for HRQOL outcomes

Abbreviations: cCBT=computerized cognitive behavioral therapy; CI=confidence interval; Dep Sxs=depressive symptoms; HRQoL=health-related quality of life; MDD=major depressive disorder

We used a mixed-treatment effects subgroup analysis across all 17 comparisons in patients with depression to examine the influence of the level of support. In the four studies with five cCBT-NS interventions, cCBT resulted in a small difference in HRQOL compared with control groups (SMD 0.25; 95% CI, 0.07 to 0.43). Six trials (nine comparisons) of cCBT-S interventions found a small to moderate difference (SMD 0.33; 95% CI, 0.18 to 0.49) in HRQOL. In three trials with three cCBT-LS interventions, cCBT resulted in a small to moderate difference in HRQOL compared with control groups (SMD 0.40; 95% CI, 0.17 to 0.63). A mixed-treatment effects subgroup analysis did not find a significant difference in HRQOL by level of support (Q (2)=1.10, p=.58). Overall, the effects of cCBT on HRQOL in trials of depression were statistically significant but relatively small.

#### Long-Term Followup

Figure 9 shows a forest plot of SMDs for all trials conducted in patients with depressive symptoms or major depressive disorder that reported symptom severity at least 6 months after randomization. Twelve trials (16 comparisons) examining patients with depressive symptoms or disorders provided followup data at least 6 months after the baseline assessment. In the seven trials (nine comparisons) involving participants with depressive symptoms, cCBT was associated with a small difference (SMD −0.33; 95% CI, −0.53 to −0.13).

Figure 9 Forest plot of cCBT versus control in patients with major depressive disorder or depressive symptoms for most distal assessment of depression

Abbreviations: cCBT=computerized cognitive behavioral therapy; CI=confidence interval; Dep Sxs=depressive symptoms; MDD=major depressive disorder; Sx=symptom

In the five trials (seven comparisons) of participants with major depressive disorder, cCBT was associated with a similarly small difference (SMD −0.28; 95% CI, −0.55 to −0.01). A mixed-treatment effects subgroup analysis found no significant difference between depressive symptom and major depressive disorder samples (Q (1)=0.57, p=.45). Compared with the effect sizes for end-of-treatment outcomes, longer term followup data from trials of major depressive disorder suggested diminishing effects at followup. Due to the relatively small number of comparisons with 6-month followup data for both treatment and control groups, subgroup analyses examining level of support and type of control group are not included in this report. Overall, for the trials providing followup data on patients with depressive symptoms or major depressive disorder, the differences in outcomes for the cCBT groups compared with the control groups were small.

### Effects of cCBT Interventions in Patients With Anxiety Disorders

#### End-of-Treatment Outcomes

Seventeen trials (19 comparisons) examining patients with anxiety symptoms or disorders provided end-of-treatment outcome data. Only trials of generalized anxiety disorder and panic disorder had enough comparisons to calculate a valid summary SMD. Figure 10 shows a forest plot of SMDs for all comparisons in participants with generalized anxiety disorder or panic disorder. Four trials (five comparisons) in patients with generalized anxiety disorder found that cCBT was associated with a large difference compared with control groups (SMD −0.94; 95% CI, −1.34 to −0.54). Significance testing provided no strong evidence of heterogeneity (Q (4)=5.867, p=.209; I^2^ = 32%). Seven trials (eight comparisons) examining patients with panic disorder found that cCBT was also associated with a large difference compared with control groups (SMD −1.08; 95% CI, −1.45 to −0.72). However, there was evidence of heterogeneity between studies (Q (7)=19.80, p<.01; I^2^=64%).

Figure 10 Forest plot of cCBT versus control in patients with generalized anxiety disorder and panic disorder

Abbreviations: cCBT=computerized cognitive behavioral therapy; CI=confidence interval; GAD=generalized anxiety disorder; PD=panic disorder; Sx=symptom

##### Anxiety Symptoms

Two trials (two comparisons) examining patients with significant anxiety symptoms provided end-of-treatment outcome data. One found that cCBT was associated with a small difference (SMD −0.28; 95% CI, −0.74 to 0.18) that was not statistically significant.76 Similarly, the other trial of participants meeting panic symptom thresholds found that cCBT was associated with a small to moderate difference (SMD −0.42; 95% CI, −0.94 to 0.10), which was not statistically significant.77

##### Depression, Anxiety, or Mixed Anxiety/Depression

Two trials (two comparisons) examining effects of cCBT in participants with a mixed group of disorders found that differences in favor of cCBT were similar. One study yielded a difference of −0.50 (95% CI, −0.91 to −0.08),70 while the other found a difference of −0.50 (95% CI, −0.79 to −0.21).68

##### Posttraumatic Stress Disorder

Two trials (two comparisons) assessing PTSD both trended in the direction of symptom reduction in the cCBT group, but neither was statistically significant. The differences in these two studies were −0.42 (95% CI, −1.13 to 0.29)61 and −0.46 (95% CI, −1.09 to 0.17).47

#### Subgroup Analyses

To examine treatment heterogeneity, we conducted mixed-treatment effects subgroup analyses for two prespecified factors: (1) level of cCBT support and (2) type of control group.

##### Level of cCBT Support

Because of the insufficient number of trials conducted in patients with other disorders, our additional analyses of level of cCBT support focused on trials in those with generalized anxiety disorder or panic disorder. Figure 11 shows a forest plot of SMDs for all comparisons in participants with generalized anxiety disorder or panic disorder. Analyses of the influence of level of support on effect sizes examined 13 comparisons among 10 trials and found an association (Q (2)=14.70, p=.001), explaining 25 percent of the observed variability in treatment effect. However, this analysis was limited by the absence of studies in the cCBT-NS category and only one study in the cCBT-AT category. Seven trials (eight comparisons) of cCBT-S interventions compared with control resulted in a large difference in favor of cCBT (SMD −0.73; 95% CI, −0.96 to −0.50). Unfortunately, it is difficult to evaluate the cCBT-LS interventions because of an insufficient number of trials using more intensive support to treat generalized anxiety disorder or panic disorder.

Figure 11 Forest plot of cCBT versus control in patients with generalized anxiety disorder and panic disorder by level of support

Abbreviations: CI=confidence interval; cCBT=computerized cognitive behavioral therapy; S=support; LS=live support; Sx=symptoms; AT=adjunct to therapy

##### Type of Control Group

Examination of potential influences of the type of control group on effect sizes in trials of generalized anxiety disorder or panic disorder included the same 13 comparisons across 10 trials used to evaluate the level of support. Nine trials (10 comparisons) compared cCBT interventions with waitlist control, and 2 trials (3 comparisons) compared cCBT with an attention/information control group. No studies used treatment as usual for the control group. A mixed-treatment effects subgroup analysis showed no evidence of differences in treatment effect by type of control group (Q (1)=0.003, p=.87).

#### Health-Related Quality-of-Life Outcomes

HRQOL data were available for three trials (three comparisons) of generalized anxiety disorder and five trials (seven comparisons) of panic disorder. The comparisons involving generalized anxiety disorder showed a moderate difference indicating a better effect in cCBT groups compared with control groups (SMD 0.57; 95% CI, 0.27 to 0.87). A similar moderate difference was observed in the panic disorder comparisons (SMD 0.49; 95% CI, 0.23 to 0.75).

There were also some data for other patient groups. Two comparisons for samples with mixed anxiety and depressive symptoms resulted in a small to moderate difference on HRQOL outcomes (SMD 0.30, 95% CI, −0.10 to 0.69^70^ and SMD 0.42, 95% CI, 0.15 to 0.69^68^). One comparison reporting HRQOL in PTSD found an SMD of 0.60 (95% CI, −0.04 to 1.23).47 For generalized anxiety disorder and panic disorder, end-of-treatment data suggest a moderate level of improvement in HRQOL.

#### Long-Term Followup

Due to the lack of trials reporting at least 2 months of followup data for cCBT interventions for anxiety disorders, no summary mean differences are available. Effect sizes were generally small to moderate. Our review found one comparison in a trial enrolling patients on the basis of baseline anxiety symptoms (SMD −0.21; 95% CI, −0.82 to 0.40),69 two comparisons of generalized anxiety disorder (SMD −0.48; 95% CI, −1.09 to 0.14^40^ and SMD −0.14; 95% CI, −0.69 to 0.41^46^), two comparisons of mixed anxiety and depressive symptoms (SMD −0.43; 95% CI, −0.87 to 0.01^70^ and SMD −0.40; 95% CI, −0.69 to −0.10^68^), and one comparison from a PTSD sample (SMD −0.94, 95% CI, −1.92 to 0.04).61 We did not conduct additional analyses of potential influences of level of support or type of control group.

### Treatment Adherence for All Clinical Disorders

Treatment adherence was reported as the percentage of patients completing all planned sessions or as the mean number of sessions completed. These data were reported in 27 of the 43 trials included in KQ 1 (33 comparisons). Patients completing the intervention was reported in 24 trials (30 comparisons), shown in Table 6. The mean number of sessions completed was reported in 16 trials (20 comparisons), shown in Table 7. Sessions completed was relatively consistent (median 65%, range 25–93%). Studies reporting completion rates found substantial variability in the proportion of participants completing the treatment (median 49.5%; range 11% to 100%). While treatment completion was quite high in several interventions, it was quite low in several interventions. Low adherence may account for diminished treatment effects in some studies.

Table 6 Treatment adherence: percentage of patients completing all sessions by condition

Condition | cCBT level | Patients completing intervention | Patients starting intervention | Percentage completing
Depressive symptoms
de Graaf, 2009 | NS | 12 | 95 | 13%
de Graaf, 2009 | NS | 36 | 95 | 38%
Farrer, 2011 | NS | 6 | 38 | 16%
Farrer, 2011 | LS | 7 | 41 | 17%
Griffiths, 2012 | NS | 32 | 73 | 44%
Griffiths, 2012 | NS | 48 | 74 | 65%
Lintvedt, 2013 | NS | 42 | 81 | 52%
Moritz, 2013 | NS | 82 | 105 | 78%
Spek, 2007 | NS | 49 | 102 | 47%
van Bastelaar, 2008 | S | 53 | 125 | 42%
van der Zanden, 2012 | LS | 24 | 121 | 20%
Warmerdam, 2008 | S | 33 | 88 | 38%
Warmerdam, 2008 | S | 34 | 88 | 39%
Major depressive disorder
Andersson, 2005 | S | 24 | 57 | 42%
Berger, 2011 | NS | 9 | 25 | 36%
Berger, 2011 | S | 14 | 25 | 56%
Carlbring, 2013 | S | 11 | 40 | 28%
Choi, 2012 | LS | 17 | 25 | 68%
Perini, 2009 | S | 20 | 27 | 74%
Titov, 2010 | LS | 32 | 46 | 70%
Titov, 2010 | LS | 33 | 41 | 80%
Williams, 2013 | LS | 19 | 25 | 76%
Wright, 2005 | AT | 13 | 13 | 100%
Generalized anxiety disorder
Paxling, 2011 | S | 4 | 38 | 11%
Titov, 2009 | LS | 18 | 24 | 75%
Panic disorder
Carlbring, 2006 | LS | 24 | 30 | 80%
Klein, 2006 | S | 18 | 19 | 95%
Silfvernagel, 2012 | S | 7 | 29 | 24%
Wims, 2010 | S | 23 | 29 | 79%
Mixed
Newby, 2013 | LS | 41 | 46 | 89%

Abbreviations: AT=adjunct to therapy; cCBT=computerized cognitive behavioral therapy; LS=live support; NS=no support

Table 7 Treatment adherence: mean and percentage of sessions completed by condition

Condition | cCBT level | Mean sessions completed | Sessions planned | Percentage sessions completed
Depression symptoms
Farrer, 2011 | NS | 1.5 | 6 | 25%
Farrer, 2011 | LS | 2 | 6 | 33%
Griffiths, 2012 | NS | 8 | 12 | 66%
Griffiths, 2012 | NS | 10 | 12 | 83%
Lintvedt, 2013 | NS | 3.1 | 5 | 62%
Moritz, 2013 | NS | 6.3 | 10 | 63%
van der Zanden, 2012 | LS | 3.2 | 6 | 53%
Major depressive disorder
Andersson, 2005 | S | 3.7 | 10 | 37%
Berger, 2011 | NS | 6.8 | 10 | 68%
Berger, 2011 | S | 8.5 | 10 | 85%
Carlbring, 2013 | S | 5.1 | 7 | 73%
Choi, 2012 | LS | 5.56 | 6 | 93%
Johansson, 2012 | S (s) | 6.5 | 8 | 81%
Johansson, 2012 | S (t) | 7.5 | 9.7 | 77%
Generalized anxiety disorder
Andersson, 2012 | S | 5.1 | 8 | 64%
Paxling, 2011 | S | 4.8 | 8 | 60%
Panic disorder
Carlbring, 2006 | LS | 8.9 | 10 | 89%
Silfvernagel, 2012 | S | 5 | 8 | 63%
Anxiety symptoms
Kenardy, 2006 | NS | 3.3 | 6 | 55%
Mixed
Newby, 2013 | LS | 5.6 | 6 | 93%

Abbreviations: AT=adjunct to therapy; cCBT=computerized cognitive behavioral therapy; LS=live support; NS=no support; (s)=standard; S=support; (t)=tailored

To explore the influence of psychiatric condition on adherence, we further examined treatment completion by condition type. While these data were only available in 24 trials, some basic differences were observed, resulting in a statistically significant difference across condition (Q(4) = 45.86, p<.01). In 13 comparisons of participants with depressive symptoms, the median completion rate was 39% (range 13% to 78%). In nine comparisons of participants with major depressive disorder, the median completion rate was 68% (range 28% to 100%). In the four studies reporting panic disorder, completion rates had a median of 79.5% (range 24% to 95%). In two studies reporting generalized anxiety disorder, the completion rates were 11 percent and 75 percent. Finally, in one study of mixed disorders, the completion rate was 89 percent. Generally, completion was lower for the depressive symptoms group, which did not receive diagnostic assessment.

## KEY QUESTION 2 For cCBT interventions, what level, type, and modality of user support is provided (e.g., daily telephone calls, weekly email correspondence); who provides this support (e.g., therapist, graduate student, peer); what is the clinical context (primary intervention, adjunct); and how is this support related to patient outcomes?

### Key Points

- Of the 57 cCBT intervention arms examined, 15 (26.3%) were classified as not supported, 26 (45.6%) were supported, 14 (24.6%) were supported with live features, and 2 (3.5%) were used as adjuncts to therapy.
- All but three trials allowed patients to access the program from a nonclinical location (e.g., home, library, or community facility), and an advertisement on the internet was the most common means of recruitment (53%).
- Most trials used email in some form (74%), while phone support by clinical staff (35%) and peer support via discussion board or chat room (25%) were used less often. Instant messaging was used in one study.
- The intervention components of studies classified as supported and supported with live features were highly variable, making firm conclusions difficult to draw.
- Exploratory subgroup analysis, using indirect comparisons, showed an association between higher levels of support and greater treatment effects. Two small studies directly compared different levels of therapist support and did not find a differential treatment effect.

### Overview of cCBT Programs

Overall, cCBT interventions lasted from 5 to 16 weeks and were designed around a median of 7 treatment modules. Over half (53%) of the interventions were 8 to 9 weeks in duration. Eighty-five percent of interventions contained 6 to 10 treatment modules. Thirty-one trials used preexisting cCBT programs.42–45,48,49,51–53,56–62,65,68,70–73,75,77,78,80–85 The other 16 trials developed their own programs or did not name a preexisting program.39–41,46,47,50,54,55,63,64,66,67,69,74,76,79

The available programs used for each disorder were different. For major depressive disorder, the Sadness Program was used four times and Deprexis^®^ was used once. For depressive symptoms, MoodGYM was used four times; Color Your Life, E-couch, and adaptations of Coping with Depression were each used twice. Overcoming Depression over the Internet, Master Your Mood, and the Wellness Workshop CD were each used once. The Worry Program was used in three of the four trials of generalized anxiety disorder. Panic Online was used three times, and the Panic Program was used once in trials for panic disorder. DE-STRESS was used in one of the two trials on PTSD. Interapy^®^ was used in one of the two trials on anxiety symptoms. Beating the Blues^®^ and a combination of Worry and Sadness programs were used in the three trials examining mixed depression and anxiety. In the trials we examined, authors tended to develop their own programs when addressing a full diagnosis. In interventions targeting major depressive disorder, six trials (55%) used preexisting computerized therapy programs,43,45,52,57,80,81 while the other five devised their own programs.39,54,55,64,67 However, for depressive symptoms, most trials (80%) used preexisting computerized therapy programs.42,44,48,49,56,58,60,62,71,72,78,82–84

Table D-2 in Appendix D describes the particular components delivered in the cCBT programs, which included psychoeducation, cognitive restructuring, behavioral activation, breathing retraining, progressive muscle relaxation, interoceptive and situational-graded exposure, and relapse prevention. In many cases, the components of the intervention were not well described, especially the presence or absence of psychoeducation, which was a part of most of the cCBT programs. All of the cCBT interventions featured cognitive restructuring and used homework in some form, but the type of homework and how well it was completed was often not addressed. For depressive disorders, the other components most commonly found were behavioral activation and modification of lifestyle factors. For panic disorder, PTSD, and anxiety symptoms, the other major components were exposure, relaxation, and relapse prevention. For generalized anxiety disorder, interpersonal skills and lifestyle factors were emphasized.

### Study Characteristics

For KQ 2, all 47 included trials used at least one category of cCBT intervention (defined in Methods). Ten trials39,44,45,52–54,56,58,72,75 contained more than one cCBT study arm, usually differing in degree of support, for a total of 57 cCBT arms across the 47 trials. Table 8 summarizes the intervention characteristics, and Tables D-3 and D-4 in Appendix D provide detailed descriptions of the interventions and types of support for each of the 57 arms, organized by target condition.

Table 8 Intervention characteristics of cCBT programs

Intervention characteristics (57 arms unless otherwise noted) | Number of arms
Category for degree of clinical support:
No support | 15
Support | 26
Live support | 14
Adjunct to therapy | 2
Technical support to navigate program provided:
Yes | 17
No/not reported | 40
Number of treatment modules: median (range) | 7 (5 to 12)
Duration of intervention in weeks: median (range) | 8 (5 to 16)
Setting where cCBT was delivered:
Nonclinical (e.g., home, work, library, other community setting) | 54
Clinical (i.e., at the therapist’s or general practitioner’s office or clinic) | 3
Therapist training (n=42 arms):^a^
Licensed professional | 13
Supervised trainee | 14
Study used both licensed professionals and trainees | 5
“Other” staff | 7
Not reported | 3
Therapist time spent on intervention communications (n=42 arms):^a^
Estimate of minutes per patient per week: median (range)^b^ | 13.5(<10 to 90)
Not reported | 7 arms
Highly variable | 4 arms
Mode of communication with therapist (n=42 arms):^a^
Email, text, or instant messaging | 33
Reminder to complete modules only | 11
Not reported | 11
Other | 2
Telephone conversation | 12
Only called if needed (e.g., did not respond to email) | 8
No/not reported | 37
Peer component (online discussion forum or chat room:^c^
Yes | 14
No/not reported | 43

a These characteristics apply only to 42 of the 57 intervention arms since they are not applicable to arms categorized as “no support.”

b The maximum of the range represents one study42 that used a 90-minute chat room as a vehicle for group therapy for five patients at a time.

c These characteristics are for all 57 arms since one of the “no support” arms used an online support group that was moderated only for observation of the group rules.

#### Setting and Clinical Context of cCBT Interventions

The most common means of patient recruitment was over the internet, usually via a website on mental health disorders (25 studies, 53%). Fifteen of these trials also used more traditional means of advertisement (newspapers, newsletters, mailings). Over 50 percent of trials that sought patients with major depressive disorder, generalized anxiety disorder, or panic disorder used the internet as the primary means of recruitment. One of the web-only trials61 was a Department of Defense website seeking PTSD cases from the 9/11 attack on the Pentagon.

Nine trials recruited patients from clinics.49,50,55,67–71,78 These included one71 that recruited patients from the membership rolls of a health maintenance organization, both of the cCBT-AT trials,67,69 and the two trials that located the program in the general practitioner’s office.68,70 Otherwise, there was no pattern based on the degree of support provided or the diagnosis sought.

Eleven of the remaining 13 trials recruited via newspaper advertisements, mailings, or waitlists from previous studies. One trial44 invited callers to a 24-hour counseling line to participate. One trial examining the effect of cCBT on anxiety symptoms76 recruited students from college psychology classes. A majority of trials (70%) allowed concurrent, stable doses of psychotropic medications; 13 percent excluded patients taking psychotropic medication while 17 percent did not report how medication was handled.

All but three trials allowed patients to access the program from a nonclinical location (e.g., home, a library, or other community facility). Two trials that addressed depression, anxiety, or mixed depression and anxiety68,70 located the cCBT program in the general practitioner’s office, and one cCBT-AT intervention67 located the program in the therapist’s office.

#### Modalities of cCBT Communication

We classified 13 trials (15 arms) as unsupported (cCBT-NS).44,45,56,62,68,70–72,76,78,82–84 Most of the trials addressed subthreshold symptoms of depression or anxiety and did not provide support beyond automated feedback given within the cCBT program. Studies that used automated emails to remind participants to complete modules were also considered cCBT-NS.

Two trials (two arms) used cCBT as an adjunct to face-to-face therapy (cCBT-AT).67,69 Wright et al.67 addressed major depressive disorder by splitting a standard 50-minute therapy session into 25 minutes spent with a therapist in-person (PhD, MD, MS, or LCSW) and 25 minutes spent working through a computer module that complemented the therapy in the clinician’s office. Kenardy et al.69 addressed panic disorder with six full therapy sessions plus the provision of an auxiliary palmtop device providing supportive information, exposure exercises, and five prompts per day to practice the exposure exercises.

Of the 40 remaining arms, the cCBT intervention was supported by study staff to varying degrees through email, text, instant messaging, phone, discussion forums, or chat rooms. We classified 22 trials (26 arms) as supported interventions (cCBT-S).39–41,45,46,48–51,54,57–60,64–66,74,75,77,79,80 Twelve trials (14 arms) used live support (cCBT-LS).42–44,47,52,53,55,61,63,73,81,85 We found these classifications occasionally difficult to make as some of these studies employed different types of media to very different degrees.

##### Email and Texting

Communication was most often described as bidirectional (i.e., both staff-to-patient and patient-to-staff). It was unclear in five trials49,54,58,59,64 whether participants could contact staff or their assigned therapist. Forty-four arms used email or text as a mode to communicate with patients. Thirty-three of these arms used email to provide support and feedback on homework. Of the 24 studies that reported amount of time spent by the therapist on email communication per patient per session (which did not include instant messaging or online groups), the median was 13.5 minutes, but varied from less than 10 minutes to 90 minutes. Four trials used email only to send reminders to patients and used a different medium (instant messaging, phone, or chat room) for the therapeutic communication. For example, Kessler et al.55 used instant messaging to conduct a standard 50- to 55-minute therapy session over the internet; an email simply reminded the participant of the appointment.

##### Phone Conversations

Ten trials (12 arms) used phone conversations weekly or as needed. Six arms recommended phone conversations be kept to 10 minutes per week; other durations of phone conversations were variable or not reported.43,44,47,52,60,61,63,73,81,85 For example, Choi et al.43 provided each patient with a weekly phone call from a Chinese-speaking therapist that could last as long as a standard therapy session. In another six trials (eight arms),49,51,53,54,72,82 the call was limited to reminding the patient to work on the module or move to the next module; or the patient was called only when he or she did not respond to email or did not log on for several weeks.

##### Online Peer Communication

Fourteen arms used some type of online peer communication. One trial arm42 used a 90-minute chat room in place of a therapy session for five patients at a time. Eleven trials used moderated discussion forums where patients could post questions or comments.47,48,50–53,57,63,64,66,73 Therapists responded within 72 hours. One arm of a cCBT-NS intervention provided a moderated support forum, but the moderator did not participate except to enforce forum conduct rules.72 One study for Chinese-speaking participants43 provided translations of previous online discussion groups.

All 27 trials treating major depressive disorder, panic disorder, generalized anxiety disorder, or PTSD were supported interventions to some degree except for one arm of a depression study;45 however, at least 50 percent of the trials on depressive and anxiety symptoms were not supported interventions. Thus, there was a qualitative correlation between increased support and increased illness severity. In cCBT-S studies, it was common for therapists to interact with patients on a weekly basis. Similarly, interventions that addressed a mental health diagnosis such as major depressive disorder tended to be longer—up to 16 weeks—than interventions aimed at addressing subthreshold mental health symptoms, which lasted up to 12 weeks.

#### Who Provides cCBT Intervention Support?

Support for cCBT was provided by licensed professionals (i.e., MD, PhD, MS, or LCSW) in 13 trials (13 arms)47,49,50,52,53,55,57,59,67,69,73,79,81 and by graduate students supervised by a licensed professional, usually at the PhD level, in 11 trials (14 arms).39–41,43,46,48,54,58,63,66,80 In four trials (five arms), both professionals and students were used as therapists,45,65,75,77 while in seven trials (seven arms), staff was described as “mental health promotion workers,” “trained lay counselors,” or “technicians.”42,44,51–53,60,85 Training level of the therapists was not reported in four trials.60,61,64,74 One study arm45 did not provide staff support.

Support was given more often by licensed professionals when the intervention was used to treat patients with full criterion diagnosis of a disorder, rather than simply exceeding a symptom threshold on a severity measure. Again, using major depressive disorder compared with depressive symptoms as an example, support in the major depressive disorder trials was provided by licensed professionals in 40 percent of the arms. By contrast, support provided for patients enrolled for depressive symptoms was given via supervised graduate students or lay support staff in all but one instance (5%).79

#### Relationship Between cCBT Support and Patient Outcomes

We considered two types of analyses to examine the relationship between level of support and treatment outcomes. First we used mixed-treatment effects subgroup analyses, which examined whether treatment effects varied across studies with differing levels of support for the cCBT intervention. These indirect comparisons—reported in detail in KQ 1—are subject to confounding and should be considered exploratory. In this section, we summarize patterns across conditions. Second, we used direct comparisons of different levels of therapist support. While these trials have the potential to give the most robust evidence, only two small studies made direct comparisons.

Another challenge was the difficulty of classifying intervention arms into differing levels of support and the variability within those categories. For example, we categorized a large set of studies as cCBT-S (supported). This designation covered a broad scope: the amount of email contact was highly variable (as described previously); the content of contacts ranged from simple encouragement to detailed feedback on homework assignments; and half these trials included a discussion forum while the other half did not. The same breadth of scope held true for the cCBT-LS (live support) interventions: contact varied from a phone call lasting less than 10 minutes once a week to a 90-minute chat room session in addition to individual contact.

##### Indirect Comparisons

The results of the mixed-treatment effect subgroup analyses, using symptom severity at end of treatment, are summarized in Table 9. Because there were relatively few trials for each condition, we conducted analyses separately for all depressive disorders and those for generalized anxiety disorder combined with panic disorder. For both of these analyses, there was a strong association between the level of cCBT support and the treatment effect (p<0.001). For trials of generalized anxiety disorder and panic disorder, there were no unsupported interventions and only one intervention using cCBT-AT (adjunct to therapy). Therefore, that analysis primarily compares cCBT-S with cCBT-LS. Because each of these analyses included only a single intervention using cCBT-AT, we conducted a sensitivity analysis that excluded these studies. For depressive disorders and anxiety disorders, the association between level of cCBT support and treatment effect remained statistically significant.

Table 9 Mixed-treatment effects in indirect comparisons

Disorder | cCBT-NS SMD (95% CI) | cCBT-S^a^ SMD (95% CI) | cCBT-LS SMD (95% CI) | cCBT-AT SMD (95% CI)
Major depressive disorder and depressive symptoms | N=12 −0.37 (−0.50 to −0.24) | N=13 −0.54 (−0.69 to −0.40) | N=7 −0.85 (−1.05 to −0.64) | N=1 −1.33 (−2.17 to −0.49)
Depressive symptoms | N=11 −0.35 (−0.47 to −0.23) | N=5 −0.40 (−0.57 to −0.22) | N=2 −0.81 (−1.15 to −0.47) | No studies
Major depressive disorder | N=1 −1.13 (−1.84 to −0.41) | N=8 −0.74 (−0.94 to −0.55) | N=5 −0.81 (−1.00 to −0.61) | N=1 −1.33 (−2.17 to −0.49)
Generalized anxiety disorder and panic disorder | No studies | N=8 −0.73 (−0.96 to −0.50) | N=4 −1.20 (−1.48 to −0.92) | N=1 −1.97 (−2.50 to −1.44)

a Wagner, 2013; Bergstrom, 2010; Carlbring, 2005 and Kiropoulos, 2008, are not included in this analysis because the control group is active (face-to-face therapy) rather than inactive (e.g., waitlist).

Abbreviations: AT=adjunct to therapy; cCBT=computerized cognitive behavioral therapy; CI=confidence interval; LS=live support; N=number of studies; NS=no support; S=support; SMD=standardized mean difference

For major depressive disorder and depressive symptoms, there were sufficient studies to analyze the level of support for each disorder separately. This stratified analysis has the advantage of controlling for the disorder but has lower statistical power since there are few studies in some categories. For depressive symptoms, there remained an association between level of cCBT support and treatment effect (p=0.04); for major depressive disorder, there was no association.

For depressive disorders, the effect was diminished, but the general pattern remained when we examined differences at the most distal time point (≥6 months, 16 arms; data not shown). Few anxiety trials reported distal outcomes, and treatment effects did not vary by condition for the anxiety disorders, so we did not analyze these data further.

##### Direct Comparisons and Subgroup Analyses

There were only three trials, two with low risk of bias45,54 and one with moderate risk of bias,44 that examined different levels of cCBT support. Farrer et al.44 examined the use of an available cCBT program, MoodGYM, with and without the support of a weekly phone call from a lay counselor (length of call not reported) in 155 participants with depressive symptoms recruited from a national telephone helpline service. Although depression scores on the CES-D scale were lower in both cCBT conditions with and without phone support compared with treatment as usual, the study did not find a difference between the two cCBT interventions. SMDs were −13.9 (NR) for cCBT with phone tracking compared with −10.6 (NR) for cCBT only (p=NS).

Berger et al.45 examined the use of another available cCBT program, Deprexis, with and without the support of a weekly email providing feedback on homework and progress through the program (about 10 minutes per week) in 76 participants with major depressive disorder recruited from website advertisements. Again, although depression scores on the Beck Depression Inventory-II (BDI-II) were lower in both cCBT conditions with and without email support compared with waitlist, the trial did not find a significant difference between the cCBT interventions. Mean differences were −12.5 (NR) for “guided self-help” (cCBT with email feedback) compared with −9.0 (NR) for “unguided self-help” (cCBT only) (p=NS). This trial was confounded by the fact that the diagnosis was made via an initial phone call from a therapist in both groups.

Vernmark et al.54 evaluated the effects of a standardized cCBT program developed for an earlier study64 with positive reinforcement on progress via email (therapist time 53 ± 28 total minutes per patient) versus a tailored cCBT program delivered via email, essentially “email therapy,” (509 ± 176 total minutes per patient) in 88 patients with major depressive disorder recruited via university media. As in the other two studies, depression scores on both the BDI-II and the Montgomery-Asberg Depression Rating Scale (MADRS) were significantly lower in both cCBT conditions compared with control conditions. The difference between guided self-help and tailored email therapy was small and favored the tailored therapy but was not significant (p=0.41). On the BDI-II, the end-of-treatment effect sizes were 2.27 (email group) compared with 1.46 (self-help group). On the MADRS, the end-of-treatment effect sizes were 2.04 (email group) compared with 1.11 (self-help group).

We examined two other variables to determine whether there was an effect from the level of cCBT support: (1) HRQOL and (2) whether the support was provided by a licensed clinician or a nonlicensed technician or lay counselor. The comparison for HRQOL had limited power due to few trials (cCBT-NS=5, cCBT-S=9, cCBT-LS=3, cCBT-AT=0). The gradient was in the expected direction (cCBT-NS=SMD +0.25; 95% CI, +0.07 to +0.43; cCBT-S=SMD +0.33; 95% CI, +0.18 to +0.49; cCBT-LS=SMD +0.40; 95% CI, +0.17 to +0.63); however, the association was not significant (p=0.58).

There were only two trials (four arms) that examined who delivered the intervention—a proxy for the importance of level of training. Studies by Titov et al.52 and Robinson et al.53 were conducted by the same group at St. Vincent’s Hospital in Sydney, Australia, using the same method adapted for two different disorders, major depressive disorder52 and generalized anxiety disorder.53 Completion rates were high in all four arms. Neither trial found significant differences due to clinician versus technician support. In Titov et al.,52 within-group effect sizes on the BDI-II were 1.27 (clinician-assisted group) and 1.20 (technician-assisted group) (p=0.07). On the Personal Health Questionnaire-9 scale, effect sizes were 1.54 (clinician-assisted group) and 1.60 (technician-assisted group) (p=0.07). In Robinson et al.,53 within-group effect sizes on the Penn State Worry Questionnaire were 1.16 (clinician-assisted group) and 1.07 (technician-assisted group) (p=0.07), and on the Generalized Anxiety Disorder-7 scale were 1.55 (clinician-assisted group) and 1.73 (technician-assisted group) (p=0.11).

In summary, indirect evidence supports a possible association between the level of cCBT support and treatment effect. A small number of trials directly comparing different levels of support did not find clinically important differences; however, these trials may be underpowered to detect a differential effect.

## KEY QUESTION 3 For adults with depressive disorder, posttraumatic stress disorder, panic disorder, or generalized anxiety disorder, what are the effects of cCBT interventions compared with face-to-face therapy?

### Key Points

- Only seven trials directly compared cCBT interventions with standard face-to-face therapy. Five trials used an internet-based platform, while two trials incorporated a computerized complement to face-to-face therapy.
- For patients with anxiety disorders or symptoms, only panic disorder had enough trials to provide a summary effect size. Evidence suggests there is minimal difference between cCBT and face-to-face therapy for panic disorder (SMD −0.07; 95% CI, −0.34 to 0.21).
- For patients with depressive disorders or symptoms, more data are needed to evaluate the differential effect between cCBT and face-to-face therapy.
- No trials of this type were conducted in patients with PTSD.

### Study Characteristics

We identified 7 trials involving 664 patients that met inclusion criteria for evaluating KQ 3.^50,59,62,66,67,69,79^ Four trials focused on treatment for panic disorder, two for subthreshold depressive symptoms, and one for major depressive disorder. Risk of bias was rated low for three trials50,59,62 and moderate for four trials.66,67,69,79 Overall, the majority of trial participants were female (range 62% to 76%). Over half of the trials reported current medication use in the sample.

### Effects of cCBT Interventions in Patients With Depressive Disorders and Symptom Thresholds

#### End-of-Treatment Outcomes

In the first of three trials62,67,79 evaluating cCBT versus face-to-face therapy, Spek et al.62 randomized 301 adults over the age of 50 with subthreshold depressive symptoms into one of three groups: (1) cCBT, (2) face-to-face group treatment, or (3) waitlist. For inclusion, participants were required to have elevated symptoms of depression but were excluded if they met full diagnostic criteria for depression based on the DSM-IV. Participants underwent either an 8-week cCBT intervention or a 10-week face-to-face group intervention for depressive symptoms using the Coping with Depression (CWD) program. The cCBT protocol was based on the CWD protocol but provided no additional support (cCBT-NS). Overall, the face-to-face group completed approximately 98 percent of the sessions (9.1 of 10 sessions), while the cCBT group completed approximately 78 percent of the sessions (5.5 of 8 sessions). Therefore, the face-to-face group intervention was longer and had greater adherence. After end-of-treatment evaluation, the two treatments did not significantly differ (SMD 0.06; 95% CI, −0.21 to 0.34; p=0.66). In a followup trial assessing predictor variables, Spek et al.62 found that having higher baseline depressive symptoms, being female, and having lower neuroticism scores were associated with better outcomes regardless of treatment type.

The second trial79 also focused on subthreshold depressive symptomology in adults between the ages of 19 and 67. Treatment in both arms of the study included “intensive therapist contact” and consisted of a manual-based CBT program delivered in eight weekly sessions. The sessions were given in the same sequential order and were provided with the same psychoeducation as the face-to-face group, but the cCBT group received texts and feedback on their progress and written assignments. At baseline, there were significant differences between groups with more females in the cCBT group compared with the face-to-face group. At end of treatment, the two treatments did not significantly differ (SMD 0.01; 95% CI: −0.53 to 0.55; p=0.98). In addition, these findings remained stable at 3-month followup.

The third trial67 focused on major depressive disorder in adults between the ages of 18 and 65 who were not currently taking any antidepressant medication. Treatment in both arms of the study involved a face-to-face component to the treatment. The standard cognitive therapy program consisted of eight weekly sessions compared with a modified computerized version of the program that reduced the amount of time spent with therapist. At baseline, there were significant differences between groups, with cCBT participants reporting greater symptomatology on both the BDI-II (p=0.001) and the Automatic Thoughts Questionnaire p=0.03) compared with the face-to-face unassisted participants. At end of treatment, the two treatments did not significantly differ (SMD 0.062; 95% CI, −0.22 to 0.34; p=0.66). These findings also were maintained at both 3- and 6-month followup.

### Effects of cCBT Interventions in Patients With Panic Disorder

#### End-of-Treatment Outcomes

Three interventions were categorized as cCBT-S,50,59,66 and one used a mobile palmtop as an adjunct to therapy.69 Face-to-face therapy consisted of ten 2-hour group sessions in one study50 and ranged from 6 to 12 individual sessions in the other three studies. Figure 12 shows a forest plot of SMDs for all comparisons in participants with panic disorder, grouped by category of support. In the three comparisons, cCBT was not more effective than face-to-face therapy (SMD 0.06; 95% CI, −0.19 to 0.31). In the single study evaluating cCBT as an adjunct, symptoms improved more than face-to-face therapy (SMD −0.42; 95% CI, −0.87 to 0.02), but this result could have been due to chance.

Figure 12 Forest plot of cCBT versus face-to-face therapy in patients with panic disorder

Abbreviations: A=adjunct to therapy; cCBT=computerized cognitive behavioral therapy; S=support; Std diff=standardized difference; Sx=symptoms

#### Health-Related Quality of Life Outcomes

HRQOL outcome data were available for three comparisons across three trials of patients with panic disorder50,59,66 but were not reported in the other trials. The cCBT intervention group was not found to be significantly better compared with the face-to-face therapy group (SMD −0.07; 95% CI, −0.34 to 0.21).

#### Combined Level of Support Across Diagnosis

Because of the small number of studies, we conducted mixed-treatment effect subgroup analyses using symptom severity as the outcome, to examine the influence of level of support across all seven trials that compared cCBT with face-to-face interventions. Figure 13 shows a forest plot of SMDs for comparisons involving participants with depression or panic disorder. In the four comparisons of cCBT-S interventions, effect sizes were generally small (SMD 0.05; 95% CI, −0.18 to 0.28). The two comparisons of cCBT-AT versus face-to-face therapy resulted in moderate, but statistically nonsignificant, differences in favor of cCBT (SMD −0.37; 95% CI, −0.75 to 0.02). There was only one trial of cCBT-NS, and intervention effects did not differ.

Figure 13 Forest plot of cCBT versus face-to-face therapy in patients with depression or panic disorder by level of cCBT support

Abbreviations: AT=adjunct to therapy; cCBT=computerized cognitive behavioral therapy; CI=confidence interval; NS=no support; S=support; Std diff=standardized difference; Sx=symptom

### Treatment Adherence and Patient Satisfaction for Disorders

Treatment adherence was reported in four of the seven comparisons of cCBT and face-to-face therapy. The percentage of patients completing the intervention was reported in three comparisons, and the mean and standard deviation of sessions completed were reported in two. Adherence outcomes by study are presented in Table 10. The studies reporting the proportion of completers generally found that the majority of participants completed the face-to-face interventions, but completion was inconsistent in the cCBT intervention.62,67,79 In regard to the number of sessions completed versus planned, the cCBT patients completed on average 71.5 percent of sessions compared with 90.5 percent of face-to-face sessions.62,66

Table 10 Treatment adherence for cCBT interventions compared with face-to-face therapy

Study | Disorder | Proportion completing all planned sessions
| | cCBT | Face-to-face therapy
Spek, 2007 | Depressive symptoms | 49/102 (48%) | 94/99 (94.5%)
Wagner, 2013 | Depressive symptoms | 25/32 (78%) | 28/30 (93%)
Wright, 2005 | Major depression, dysthymia | 13/13 (100%) | 14/14 (100%)
| | Mean sessions completed/total planned sessions
Spek, 2007 | Depressive symptoms | 5.5/8 | 9.1/10
Carlbring, 2005 | Panic disorder | 7.4/10 | 9.0/10

Patient satisfaction was reported in three trials.59,66,79 Generally, the studies reported equal satisfaction between cCBT and face-to-face groups. However, participants in the face-to-face group in one trial59 reported significantly higher levels of “enjoyment for communicating with therapist.”