# REFERENCES

1 Centers for Disease Control and Prevention. Mental Illness Surveillance Among Adults in the United States. MMWR. 2011;60(Suppl). Available at http://www.cdc.gov/mmwr/preview/mmwrhtml/su6003a1.htm?s_cid=su6003a1_w. Accessed August 2, 2013.
2 Kessler R, Aguilar-Gaxiola S, Alonso J, et al. The global burden of mental disorders: an update from the WHO World Mental Health (WMH) surveys. Epidemiol Psichiatr Soc. 2009;2009(1):23-33. [pmid: 19378696].
3 World Health Organization. The Global Burden of Disease: 2004 Update. Geneva, Switzerland. WHO Press. 2008. Available at: http://www.who.int/healthinfo/global_burden_disease/2004_report_update/en/. Accessed August 2, 2013.
4 Government Accountability Office. Number of Veterans Receiving Care, Barriers Faced, and Efforts to Increase Access. 2011. Available at: http://www.gao.gov/products/GAO-12-12. Accessed August 2, 2013.
5 Kessler RC, Chiu WT, Demler O, et al. Prevalence, severity, and comorbidity of 12-month DSM-IV disorders in the National Comorbidity Survey Replication. Arch Gen Psychiatry. 2005;62(6):617-27. [pmid: 15939839].
6 Beck AT. Depression: Causes and treatment. Philadelphia, PA. University of Pennsylvania Press. 1967.
7 Beck AT, Rush AJ, Shaw BF, et al. Cognitive therapy of depression. New York, NY. Guilford Press. 1979.
8 Beck AT, Emery G. Anxiety disorders and phobias: A cognitive perspective. New York, NY. Basic Books. 1985.
9 Beck AT, Wright FD, Newman CF, et al. Cognitive therapy of substance abuse. New York, NY. Guilford Press. 1993.
10 Beck AT, Freeman A, Davis DD. Cognitive therapy for personality disorders. 2nd Ed. New York, NY. Guilford Press. 2004.
11 Fairburn CG. Cognitive-behavioral therapy for bulimia nervosa. Flach F, editor. The Hatherleigh guide to psychiatric disorders, Part II The Hatherleigh guide series. Long Island City, NY. The Hatherleigh Company. 2000:69-88.
12 Basco MR, Rush AJ. Cognitive-behavioral therapy for bipolar disorder. New York, NY. Guilford Press. 1996.
13 Beck AT, Rector NA, Stolar N, et al. Schizophrenia: Cognitive theory, research, and therapy. New York, NY. Guilford Press. 2009.
14 DeRubeis RJ, Hollon SD, Amsterdam JD. Cognitive therapy vs. medications in the treatment of moderate to severe depression. Arch Gen Psychiatry. 2005;(62):409-416. [pmid: 15809408].
15 Elkin I, Shea MT, Watkins JT. National Institute of Mental Health Treatment of Depression Collaborative Research Program: General effectiveness of treatments. Arch Gen Psychiatry. 1989;(46):971-982. [pmid: 2684085].
16 Hollon SD, Stewart MO, Strunk D. Enduring effects for cognitive behavior therapy in the treatment of depression and anxiety. Annu Rev Psychol. 2006;(57):285-315. [pmid: 16318597].
17 Andrews G, Cuijpers P, Craske MG, et al. Computer therapy for the anxiety and depressive disorders is effective, acceptable and practical health care: a meta-analysis. PLoS One. 2010;5(10):e13196. [pmid: 20967242].
18 Griffiths KM, Farrer L, Christensen H. The efficacy of internet interventions for depression and anxiety disorders: a review of randomised controlled trials. Med J Aust. 2010;192(11 Suppl):S4-11. [pmid: 20528707].
19 Johansson R, Andersson G. Internet-based psychological treatments for depression. Expert Rev Neurother. 2012;12(7):861-9. quiz 870. [pmid: 22853793].
20 Farvolden P, Denisoff E, Selby P, et al. Usage and longitudinal effectiveness of a Web-based self-help cognitive behavioral therapy program for panic disorder. J Med Internet Res. 2005;7(1):e7. [pmid: 15829479].
21 Christensen H, Griffiths KM, Jorm AF. Delivering interventions for depression by using the internet: randomised controlled trial. BMJ. 2004;328(7434):265. [pmid: 14742346].
22 Christensen H, Griffiths KM, Korten AE, et al. A comparison of changes in anxiety and depression symptoms of spontaneous users and trial participants of a cognitive behavior therapy website. J Med Internet Res. 2004;6(4):e46. [pmid: 15631970].
23 Spek V, Cuijpers P, Nyklicek I, et al. Internet-based cognitive behaviour therapy for symptoms of depression and anxiety: a meta-analysis. Psychol Med. 2007;37(3):319-28. [pmid: 17112400].
24 Moher D, Liberati A, Tetzlaff J, et al. Preferred reporting items for systematic reviews and meta-analyses: the PRISMA statement. PLoS Med. 2009;6(7):e1000097. [pmid: 19621072].
25 Amstadter AB, Broman-Fulks J, Zinzow H, et al. Internet-based interventions for traumatic stress-related mental health problems: a review and suggestion for future research. Clin Psychol Rev. 2009;29(5):410-20. [pmid: 19403215].
26 Andersson G. Guided internet treatment for anxiety disorders. As effective as face-to-face therapies?. Stud Health Technol Inform. 2012;181:3-7. [pmid: 22954817].
27 Andersson G, Cuijpers P. Internet-based and other computerized psychological treatments for adult depression: a meta-analysis. Cogn Behav Ther. 2009;38(4):196-205. [pmid: 20183695].
28 Cuijpers P, Marks IM, van Straten A, et al. Computer-aided psychotherapy for anxiety disorders: a meta-analytic review. Cogn Behav Ther. 2009;38(2):66-82. [pmid: 20183688].
29 Foroushani PS, Schneider J, Assareh N. Meta-review of the effectiveness of computerised CBT in treating depression. BMC Psychiatry. 2011;11:131. [pmid: 21838902].
30 Kaltenthaler E, Parry G, Beverley C, et al. Computerised cognitive-behavioural therapy for depression: systematic review. Br J Psychiatry. 2008;193(3):181-4. [pmid: 18757972].
31 Lewis C, Pearce J, Bisson JI. Efficacy, cost-effectiveness and acceptability of self-help interventions for anxiety disorders: systematic review. Br J Psychiatry. 2012;200(1):15-21. [pmid: 22215865].
32 Reger MA, Gahm GA. A meta-analysis of the effects of internet- and computer-based cognitive-behavioral treatments for anxiety. J Clin Psychol. 2009;65(1):53-75. [pmid: 19051274].
33 Tumur I, Kaltenthaler E, Ferriter M, et al. Computerised cognitive behaviour therapy for obsessive-compulsive disorder: A systematic review. Psychother Psychosom. 2007;76(4):196-202. [pmid: 17570957].
34 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville, MD. Agency for Healthcare Research and Quality. Available at: http://www.effectivehealthcare.ahrq.gov/index.cfm/searchfor-guides-reviews-and-reports/?pageaction=displayproduct&productid=318. Accessed August 5, 2013.
35 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7(3):177-88. [pmid: 3802833].
36 Deeks JJ, Higgins JPT, editors. Chapter 9: Analysing data and undertaking meta-analysis. Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0. [updated March 2011]. The Cochrane Collaboration. 2011. Available from www.cochrane-handbook.org. Accessed August 5, 2013.
37 Cohen J. Statistical power analysis for the behavioral sciences. Second edition. Hillsdale, NJ. L. Erlbaum Associates. 1988.
38 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. 2002;21(11):1539-58. [pmid: 12111919].
39 Johansson R, Sjoberg E, Sjogren M, et al. Tailored vs. standardized internet-based cognitive behavior therapy for depression and comorbid symptoms: a randomized controlled trial. PLoS One. 2012;7(5):e36905. [pmid: 22615841].
40 Andersson G, Paxling B, Roch-Norlund P, et al. Internet-based psychodynamic versus cognitive behavioral guided self-help for generalized anxiety disorder: a randomized controlled trial. Psychother Psychosom. 2012;81(6):344-55. [pmid: 22964540].
41 Silfvernagel K, Carlbring P, Kabo J, et al. Individually tailored internet-based treatment for young adults and adults with panic attacks: randomized controlled trial. J Med Internet Res. 2012;14(3):e65. [pmid: 22732098].
42 van der Zanden R, Kramer J, Gerrits R, et al. Effectiveness of an online group course for depression in adolescents and young adults: a randomized trial. J Med Internet Res. 2012;14(3):e86. [pmid: 22677437].
43 Choi I, Zou J, Titov N, et al. Culturally attuned Internet treatment for depression amongst Chinese Australians: a randomised controlled trial. J Affect Disord. 2012;136(3):459-68. [pmid: 22177742].
44 Farrer L, Christensen H, Griffiths KM, et al. Internet-based CBT for depression with and without telephone tracking in a national helpline: randomised controlled trial. PLoS One. 2011;6(11):e28099. [pmid: 22140514].
45 Berger T, Hammerli K, Gubser N, et al. Internet-based treatment of depression: a randomized controlled trial comparing guided with unguided self-help. Cogn Behav Ther. 2011;40(4):251-66. [pmid: 22060248].
46 Paxling B, Almlov J, Dahlin M, et al. Guided internet-delivered cognitive behavior therapy for generalized anxiety disorder: a randomized controlled trial. Cogn Behav Ther. 2011;40(3):159-73. [pmid: 21770848].
47 Spence J, Titov N, Dear BF, et al. Randomized controlled trial of Internet-delivered cognitive behavioral therapy for posttraumatic stress disorder. Depress Anxiety. 2011;28(7):541-50. [pmid: 21721073].
48 van Bastelaar KM, Pouwer F, Cuijpers P, et al. Web-based depression treatment for type 1 and type 2 diabetic patients: a randomized, controlled trial. Diabetes Care. 2011;34(2):320-5. [pmid: 21216855].
49 Levin W, Campbell DR, McGovern KB, et al. A computer-assisted depression intervention in primary care. Psychol Med. 2011;41(7):1373-83. [pmid: 20961474].
50 Bergstrom J, Andersson G, Ljotsson B, et al. Internet-versus group-administered cognitive behaviour therapy for panic disorder in a psychiatric setting: a randomised trial. BMC Psychiatry. 2010;10:54. [pmid: 20598127].
51 Wims E, Titov N, Andrews G, et al. Clinician-assisted Internet-based treatment is effective for panic: A randomized controlled trial. Aust N Z J Psychiatry. 2010;44(7):599-607. [pmid: 20560847].
52 Titov N, Andrews G, Davies M, et al. Internet treatment for depression: a randomized controlled trial comparing clinician vs. technician assistance. PLoS One. 2010;5(6):e10939. [pmid: 20544030].
53 Robinson E, Titov N, Andrews G, et al. Internet treatment for generalized anxiety disorder: a randomized controlled trial comparing clinician vs. technician assistance. PLoS One. 2010;5(6):e10942. [pmid: 20532167].
54 Vernmark K, Lenndin J, Bjarehed J, et al. Internet administered guided self-help versus individualized e-mail therapy: A randomized trial of two versions of CBT for major depression. Behav Res Ther. 2010;48(5):368-76. [pmid: 20152960].
55 Kessler D, Lewis G, Kaur S, et al. Therapist-delivered Internet psychotherapy for depression in primary care: a randomised controlled trial. Lancet. 2009;374(9690):628-34. [pmid: 19700005].
56 de Graaf LE, Gerhards SA, Arntz A, et al. Clinical effectiveness of online computerised cognitive-behavioural therapy without support for depression in primary care: randomised trial. Br J Psychiatry. 2009;195(1):73-80. [pmid: 19567900].
57 Perini S, Titov N, Andrews G. Clinician-assisted Internet-based treatment is effective for depression: randomized controlled trial. Aust N Z J Psychiatry. 2009;43(6):571-8. [pmid: 19440890].
58 Warmerdam L, van Straten A, Twisk J, et al. Internet-based treatment for adults with depressive symptoms: randomized controlled trial. J Med Internet Res. 2008;10(4):e44. [pmid: 19033149].
59 Kiropoulos LA, Klein B, Austin DW, et al. Is internet-based CBT for panic disorder and agoraphobia as effective as face-to-face CBT?. J Anxiety Disord. 2008;22(8):1273-84. [pmid: 18289829].
60 Mackinnon A, Griffiths KM, Christensen H. Comparative randomised trial of online cognitive-behavioural therapy and an information website for depression: 12-month outcomes. Br J Psychiatry. 2008;192(2):130-4. [pmid: 18245031].
61 Litz BT, Engel CC, Bryant RA, et al. A randomized, controlled proof-of-concept trial of an Internet-based, therapist-assisted self-management treatment for posttraumatic stress disorder. Am J Psychiatry. 2007;164(11):1676-83. [pmid: 17974932].
62 Spek V, Nyklicek I, Smits N, et al. Internet-based cognitive behavioural therapy for subthreshold depression in people over 50 years old: a randomized controlled clinical trial. Psychol Med. 2007;37(12):1797-806. [pmid: 17466110].
63 Carlbring P, Bohman S, Brunt S, et al. Remote treatment of panic disorder: a randomized trial of internet-based cognitive behavior therapy supplemented with telephone calls. Am J Psychiatry. 2006;163(12):2119-25. [pmid: 17151163].
64 Andersson G, Bergstrom J, Hollandare F, et al. Internet-based self-help for depression: randomised controlled trial. Br J Psychiatry. 2005;187:456-61. [pmid: 16260822].
65 Klein B, Richards JC, Austin DW. Efficacy of internet therapy for panic disorder. J Behav Ther Exp Psychiatry. 2006;37(3):213-38. [pmid: 16126161].
66 Carlbring P, Nilsson-Ihrfelt E, Waara J, et al. Treatment of panic disorder: live therapy vs. self-help via the Internet. Behav Res Ther. 2005;43(10):1321-33. [pmid: 16086983].
67 Wright JH, Wright AS, Albano AM, et al. Computer-assisted cognitive therapy for depression: maintaining efficacy while reducing therapist time. Am J Psychiatry. 2005;162(6):1158-64. [pmid: 15930065].
68 Proudfoot J, Ryden C, Everitt B, et al. Clinical efficacy of computerised cognitive-behavioural therapy for anxiety and depression in primary care: randomised controlled trial. Br J Psychiatry. 2004;185:46-54. [pmid: 15231555].
69 Kenardy JA, Dow MG, Johnston DW, et al. A comparison of delivery methods of cognitive-behavioral therapy for panic disorder: an international multicenter trial. J Consult Clin Psychol. 2003;71(6):1068-75. [pmid: 14622082].
70 Proudfoot J, Goldberg D, Mann A, et al. Computerized, interactive, multimedia cognitive-behavioural program for anxiety and depression in general practice. Psychol Med. 2003;33(2):217-27. [pmid: 12622301].
71 Clarke G, Reid E, Eubanks D, et al. Overcoming depression on the Internet (ODIN): a randomized controlled trial of an Internet depression skills intervention program. J Med Internet Res. 2002;4(3):E14. [pmid: 12554545].
72 Griffiths KM, Mackinnon AJ, Crisp DA, et al. The Effectiveness of an Online Support Group for Members of the Community with Depression: A Randomised Controlled Trial. PLoS One. 2012;7(12).
73 Titov N, Andrews G, Robinson E, et al. Clinician-assisted Internet-based treatment is effective for generalized anxiety disorder: Randomized controlled trial. Aust N Z J Psychiatry. 2009;43(10):905-912.
74 Carlbring P, Westling BE, Ljungstrand P, et al. Treatment of panic disorder via the Internet: A randomized trial of a self-help program. Behav Ther. 2001;32(4):751-764.
75 Richards JC, Klein B, Austin DW. Internet cognitive behavioural therapy for panic disorder: Does the inclusion of stress management information improve end-state functioning?. Clinical Psychologist. 2006;10(1):2-15.
76 Kenardy J, McCafferty K, Rosa V. Internet-delivered indicated prevention for anxiety disorders: Six-month follow-up. Clinical Psychologist. 2006;10(1):39-42.
77 Ruwaard J, Broeksteeg J, Schrieken B, et al. Web-based therapist-assisted cognitive behavioral treatment of panic symptoms: a randomized controlled trial with a three-year follow-up. J Anxiety Disord. 2010:387-96. [pmid: 20227241].
78 Hickie IB, Davenport TA, Luscombe GM, et al. Practitioner-supported delivery of internet-based cognitive behaviour therapy: evaluation of the feasibility of conducting a cluster randomised trial. Med J Aust. 2010;(11 Suppl):S31-5. [pmid: 20528705].
79 Wagner B, Horn AB, Andreas M. Internet-based versus face-to-face cognitive-behavioral intervention for depression: A randomized controlled non-inferiority trial. J Affect Disord. 2013.
80 Carlbring P, Hagglund M, Luthstrom A, et al. Internet-based behavioral activation and acceptance-based treatment for depression: a randomized controlled trial. J Affect Disord. 2013;148(2–3):331-7. [pmid: 23357657].
81 Williams AD, Blackwell SE, Mackenzie A, et al. Combining Imagination and Reason in the Treatment of Depression: A Randomized Controlled Trial of Internet-Based Cognitive-Bias Modification and Internet-CBT for Depression. J Consult Clin Psychol. 2013.
82 Glozier N, Christensen H, Naismith S, et al. Internet-Delivered Cognitive Behavioural Therapy for Adults with Mild to Moderate Depression and High Cardiovascular Disease Risks: A Randomised Attention-Controlled Trial. PLoS One. 2013;8:3. Article Number: e59139.
83 Lintvedt OK, Griffiths KM, Sorensen K, et al. Evaluating the effectiveness and efficacy of unguided internet-based self-help intervention for the prevention of depression: a randomized controlled trial. Clin Psychol Psychother. 2013;20(1):10-27. [pmid: 21887811].
84 Moritz S, Schilling L, Hauschildt M, et al. A randomized controlled trial of internet-based therapy in depression. Behav Res Ther. 2012;50:513-21. [pmid: 22677231].
85 Newby JM, Mackenzie A, Williams AD, et al. Internet cognitive behavioural therapy for mixed anxiety and depression: a randomized controlled trial and evidence of effectiveness in primary care. Psychol Med. 2013:1-14.
86 Butler AC, Chapman JE, Forman EM, et al. The empirical status of cognitive-behavioral therapy: a review of meta-analyses. Clin Psychol Rev. 2006;26(1):17-31. [pmid: 16199119].
87 Ekers D, Richards D, Gilbody S. A meta-analysis of randomized trials of behavioural treatment of depression. Psychol Med. 2008;38(5):611-23. [pmid: 17903337].
88 Hunot V, Churchill R, Silva de Lima M, et al. Psychological therapies for generalised anxiety disorder. Cochrane Database Syst Rev. 2007;(1):CD001848. [pmid: 17253466].
89 Karlin BE, Walser RD, Yesavage J, et al. Effectiveness of acceptance and commitment therapy for depression: comparison among older and younger veterans. Aging Ment Health. 2013;17(5):555-63. [pmid: 23607328].
90 Eftekhari A, Ruzek JI, Crowley JJ, et al. Effectiveness of national implementation of prolonged exposure therapy in veterans affairs care. JAMA Psychiatry. 2013;70(9):949-55. [pmid: 23863892].
91 Department of Veterans Affairs. Management of major depressive disorder (MDD). VA/DoD Clinical Practice Guidelines. 2009. Available at: http://www.healthquality.va.gov/Major_Depressive_Disorder_MDD_Clinical_Practice_Guideline.asp. Accessed August 2, 2013.
92 American Psychiatric Association. Practice guideline for the treatment of patients with major depressive disorder. 3rd edition. Arlington, VA. American Psychiatric Association. 2010. Available at: http://www.psychiatry.org/practice/clinical-practice-guidelines. Accessed August 2, 2013.
93 Parikh SV, Segal ZV, Grigoriadis S, et al. Canadian Network for Mood and Anxiety Treatments (CANMAT) clinical guidelines for the management of major depressive disorder in adults. II. Psychotherapy alone or in combination with antidepressant medication. J Affect Disord. 2009;117(Suppl 1):S15-25. [pmid: 19682749].
94 National Institute for Health and Care Excellence. Depression: the treatment and management of depression in adults. NICE Clinical Guideline 90. October. 2009. Available at: http://www.nice.org.uk/nicemedia/pdf/cg90niceguideline.pdf. Accessed August 3, 2013.
95 National Institute for Health and Care Excellence. Generalised anxiety disorder and panic disorder (with or without agoraphobia) in adults: management in primary, secondary and community care. NICE Clinical Guideline 113. January. 2011. Available at: http://www.nice.org.uk/nicemedia/live/13314/52599/52599.pdf. Accessed August 12, 2013.
96 Hind D, O’Cathain A, Cooper CL, et al. The acceptability of computerised cognitive behavioural therapy for the treatment of depression in people with chronic physical disease: a qualitative study of people with multiple sclerosis. Psychol Health. 2010;25(6):699-712. [pmid: 20204955].
97 McMurchie W, Macleod F, Power K, et al. Computerised cognitive behavioural therapy for depression and anxiety with older people: a pilot study to examine patient acceptability and treatment outcome. Int J Geriatr Psychiatry. 2013.
98 Tsai J, Rosenheck RA. Use of the internet and an online personal health record system by US veterans: comparison of Veterans Affairs mental health service users and other veterans nationally. J Am Med Inform Assoc. 2012;19(6):1089-94. [pmid: 22847305].
99 Sarasohn-Kahn J. The online couch: mental health care on the web. California Healthcare Foundation. 2012. Available at: http://www.chcf.org/~/media/MEDIA%20LIBRARY%20Files/PDF/O/PDF%20OnlineCouchMentalHealthWeb.pdf. Accessed August 12, 2013.
100 Beating the Blues. Cognitive Behavioral Therapy. 2011. Available at: http://www.u2interactive.com/. Accessed August 3, 2013.
101 Robinson KA, Saldanha IJ, Mckoy NA. Frameworks for Determining Research Gaps During Systematic Reviews. Methods Future Research Needs Report No. 2. (Prepared by the Johns Hopkins University Evidence-based Practice Center under Contract No. HHSA 290-2007-10061-I.) AHRQ Publication No. 11-EHC043-EF. Rockville, MD. Agency for Healthcare Research and Quality. June. 2011. Available at: http://effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?productid=735&pageaction=displayproduct. Accessed April 8, 2012.