# METHODS

## TOPIC DEVELOPMENT

We followed a standard protocol for this review; certain methods map to PRISMA (i.e., Preferred Reporting Items for Systematic Reviews and Meta-Analyses).24 The topic was nominated after a process that included a preliminary review of published peer-reviewed literature and consultation with investigators, VA and non-VA experts, and key stakeholders (Mental Health Web Services, Mental Health Services, and Mental Health QUERI).

The Key Questions (KQs) are:

KQ 1 For adults with depressive disorder, posttraumatic stress disorder, panic disorder, or generalized anxiety disorder, what are the effects of computerized CBT (cCBT) interventions compared with inactive controls?
KQ 2 For cCBT interventions, what level, type, and modality of user support is provided (e.g., daily telephone calls, weekly email correspondence); who provides this support (e.g., therapist, graduate student, peer); what is the clinical context (primary intervention, adjunct); and how is this support related to patient outcomes?
KQ 3 For adults with depressive disorder, posttraumatic stress disorder, panic disorder, or generalized anxiety disorder, what are the effects of cCBT interventions compared with face-to-face therapy?

## ANALYTIC FRAMEWORK

Our approach was guided by the analytic framework shown in Figure 1.

Figure 1 Analytic framework for evaluating computerized CBT interventions

Abbreviations: CBT=cognitive behavioral therapy; DSM=Diagnostic and Statistical Manual of Mental Disorders; GAD=generalized anxiety disorder; KQ=Key Question; NOS=not otherwise specified; PTSD=posttraumatic stress disorder

## SEARCH STRATEGY

We conducted a primary review of the literature by systematically searching, reviewing, and analyzing the scientific evidence as it pertains to the KQs. To identify relevant articles, in consultation with a master librarian, we searched MEDLINE^®^ (via PubMed^®^), Cochrane Central Register of Controlled Trials, Embase^®^, CINAHL^®^, and PsycINFO^®^ from January 1, 1990, to August 30, 2013, for peer-reviewed publications of trials that compared cCBT with usual care or face-to-face therapy in adults with depressive symptoms or disorders, selected anxiety disorders (i.e., panic disorder or generalized anxiety disorder), and PTSD.

We used Medical Subject Heading (MeSH) terms and selected free-text terms for the conditions of interest; cognitive behavioral therapy and closely related therapies; and the electronic delivery mode, including computer-assisted, internet, and terms for mobile devices (Appendix A). We added validated search terms for RCTs. We limited the search to RCTs published in the English language. We further searched the bibliographies of exemplar trials and applicable systematic reviews for missed publications.17,18,23,25–33 To assess for publication bias, we searched www.clinicaltrials.gov to identify completed but unpublished studies meeting our eligibility criteria, an indicator of possible publication bias.

All citations were imported into two electronic databases (for referencing, EndNote^®^ Version X5, Thomson Reuters, Philadelphia, PA; for data abstraction, DistillerSR; Evidence Partners Inc., Manotick, ON, Canada).

## STUDY SELECTION

Using prespecified inclusion and exclusion criteria, two reviewers assessed titles and abstracts for relevance to the KQs. Full-text articles identified by either reviewer as potentially relevant were retrieved for further review and examined by two reviewers against the eligibility criteria. Disagreements on inclusion, exclusion, or the major reason for exclusion were resolved by discussion or by a third reviewer. The criteria to screen articles for inclusion or exclusion at both the title-and-abstract and full-text screening stages are detailed in Table 4. In addition, trials with three or more arms were examined for appropriateness of all arms for inclusion. For example, any active arm that did not include cCBT (such as a telephone-only intervention) was not abstracted for inclusion in the analysis.

Table 4 Summary of inclusion and exclusion criteria

Study Characteristic | Inclusion Criteria | Exclusion Criteria
Population | Adults (≥18 years of age) with one or more of the following conditions:; - Unipolar depressive disorder (major depressive disorder, dysthymia, minor depression, adjustment disorder with depressed mood, or mixed anxiety/depression) as defined by DSM criteria; - Posttraumatic stress disorder as defined by DSM criteria; - Generalized anxiety disorder, panic disorder, and anxiety disorder not otherwise specified as defined by DSM criteria; - Patients scoring above the threshold for significant depressive or anxiety symptoms using a validated questionnaire as a condition of eligibility; - Comorbid psychiatric disorders as long as the primary disorder is a condition of interest; - In studies that include mixed samples of children and adults, at least 80% must be ≥18 years old (or the mean age minus 1.5 SD ≥18 years old); - In studies that include patients with a large number of conditions, at least 80% must have one of the conditions of interest | Patients with test anxiety Phobias and social anxiety disorder
Intervention | Intervention must be a therapy based on cognitive behavioral therapy (CBT) and delivered primarily by a computerized (i.e., electronic) mechanism. Interventions may be designed for self-guided treatment or with the support of a clinician, but the computerized program must be the key intervention that differs from the control group.; - Delivery mode: Internet, mobile platform (e.g., smartphone), computer in clinic; - Treatment model: Therapy is CBT or derived from cognitive or behavioral therapies. CBT interventions adhere to the premise that changing maladaptive thinking leads to change in affect and in behavior. CBT includes six phases:; 1. Assessment; 2. Reconceptualization; 3. Skills acquisition; 4. Skills consolidation and application training; 5. Generalization and maintenance; 6. Posttreatment assessment followup; Therapies that are closely related to CBT and included in this review are exposure therapy, stress inoculation training, cognitive processing therapy, cognitive therapy, dialectical behavior therapy, problem solving therapy, and acceptance and commitment therapy.; - Treatment phase: Intervention is designed for acute-phase treatment, not relapse prevention or the prevention of mental illness. | Psychodynamic therapy and interpersonal therapy Interventions designed to prevent onset or relapse of mental illness Interventions that are primarily telemedicine-based (e.g., therapy via video chat or telephone interactions, including those by interactive voice response) Interventions using virtual reality as the primary therapeutic mode Therapies that do not use the key components of CBT Disease management interventions where CBT is only one component of a more comprehensive intervention Therapies that are delivered primarily in face-to-face encounters but supplemented by text messages or online materials that do not meet the definition of a CBT or CBT-related intervention
Comparator | KQ 1, KQ 2: Usual care not involving psychotherapy; waitlist control; attention/information control KQ 2: cCBT with a different level of therapist support KQ 3: Face-to-face CBT | Any comparator where the effect of the cCBT intervention cannot be isolated
Outcome | Patient experience (e.g., satisfaction measure) Adherence to the intervention (e.g., number of planned sessions completed, proportion completing the planned intervention) Validated, self-report symptom measures (e.g., BDI, HDRS) Validated, functional status measures of global or mental health functioning (e.g., SF-36, Sheehan Disability Scale) Safety outcomes such as emergency department visits or hospital admissions related to the disorder being treated; self-harm behaviors | None
Timing | Outcomes reported ≥2 months from randomization and initiation of intervention | Outcomes reported <2 months
Setting | Patients may be identified from primary care, medical specialty, mental health, or community populations Patients do not have to be engaged in treatment with a clinician and may be identified through self-assessments without a definitive clinical diagnosis | Inpatient settings
Study design | Randomized controlled trials with n >20. The sample size requirement is designed to exclude small pilot studies that typically are underpowered and have more methodological problems than larger trials. Studies with small samples sizes and no treatment effect are also less likely to be published than those finding a treatment effect, increasing the risk of publication bias. | Any study design other than RCT
Publications | English-language only Published from 1990 to present^a^ Peer-reviewed, full publication Study conducted in North America, Western Europe, Australia/New Zealand^b^ | Non-English language Published before 1990 Abstract only

a Rationale is that CBT was developed in the 1970s, personal computers in the early 1980s, and the internet in the 1990s. Based on our assessment of studies included in existing systematic reviews, the earliest relevant publication was in 1990.

b Rationale is to include economically developed countries with sufficient similarities in healthcare system and culture to be applicable to U.S. medical care.

Abbreviations: BDI=Beck Depression Inventory scale; CBT=cognitive behavioral therapy; cCBT=computerized cognitive behavioral therapy; HDRS=Hamilton Depression Rating Scale; KQ=Key Question; RCT=randomized controlled trial

## DATA ABSTRACTION

Before general use, the abstraction form templates, designed specifically for this report, were piloted on a sample of included articles and revised to ensure that all relevant data elements were captured and that there was consistency and reproducibility between abstractors. Data elements include descriptors to assess applicability, quality elements, intervention/exposure details, and outcomes. Key characteristics abstracted include patient descriptors (including education, computer skills, experience with therapy), setting, features and dose of the cCBT intervention, features of the comparator, and outcomes as described previously. Key features relevant to applicability include the match between the sample and target populations (e.g., comorbidity, age, education level) and the training and experience of the clinician. Data from published reports were then abstracted into the final abstraction form by a trained reviewer. All data abstractions were confirmed by a second reviewer. Disagreements were resolved by consensus or by obtaining a third reviewer’s opinion.

We abstracted the following key information for each included study:

- Study characteristics
  ○ Study design
  ○ Location (country) and recruitment setting (clinic, etc.) of study
  ○ Types of comparison groups
  ○ Inclusion and exclusion criteria (eligible diagnoses, etc.)
  ○ Number of participants eligible for, randomized, or enrolled in and completed study
- Population characteristics
  ○ Sex, race, and age of sample
  ○ Inclusion of active duty or Veteran participants
  ○ Psychiatric diagnoses
  ○ Baseline severity of symptoms
- Description of the intervention
  ○ “Brand” name of intervention
  ○ Components of intervention
  ○ Therapist credentials
  ○ Number of treatment modules, time allowed for completion
  ○ Level of therapist support, including homework feedback, email communication, live communication (e.g., telephone)
  ○ Technical support offered
  ○ Presence of peer support (discussion board, chat-room, etc.)
- Outcomes
  ○ Time points measured
  ○ Treatment adherence: mean sessions completed or proportion completing all sessions
  ○ Patient satisfaction
  ○ Symptom severity
  ○ Health-related quality of life (HRQOL)
  ○ Safety: emergency department visits or hospital admissions related to the disorder; self-harm behaviors

## RISK OF BIAS (QUALITY) ASSESSMENT

We abstracted data necessary to assess the risk of bias of included trials. Across all included trials, quality criteria were applied for each RCT by two independent reviewers (Appendix B). Disagreements were resolved between the two reviewers or, when needed, by arbitration from a third reviewer. We used the key risk of bias criteria described in the Agency for Healthcare Research and Quality’s (AHRQ’s) “Methods Guide for Effectiveness and Comparative Effectiveness Reviews”34 adapted to this specific topic and customized to RCTs. These criteria are adequacy of randomization and allocation concealment, the comparability of groups at baseline, blinding, the completeness of followup and differential loss to followup, whether incomplete data were addressed appropriately, the validity of outcome measures, and conflict of interest. We assigned a summary risk of bias score (low, moderate, or high) to individual studies.

## DATA SYNTHESIS

While synthesizing relevant abstracted data, we developed a summary table describing the key outcomes used to test cCBT interventions in included RCTs. We then determined the feasibility of completing a quantitative synthesis (i.e., meta-analysis) to estimate summary effects. Feasibility depends on the volume of relevant literature, conceptual homogeneity of the trials, and completeness of results reporting.

When meta-analysis was feasible, we computed summary estimates of effect, stratified by condition (e.g., major depressive disorder, panic disorder), for both end-of-treatment and longest followup point ≥6 months. Because the primary outcome—symptom severity—was measured across the trials using different instruments, the measurements of symptom severity were combined using standardized mean differences (SMDs) in a random-effects model.35,36 At each time point, the SMD was calculated by subtracting the average score of the treatment group from the average score of the control group and dividing the result by the pooled standard deviations of the two groups. SMDs of 0.2 can be considered small treatment effects; 0.5, moderate effects; and ≥0.8, large effects.37

In addition, symptom severity for a single trial was often reported using more than one instrument (e.g., Beck Depression Inventory and Hamilton Depression Rating Scale). When multiple instruments were used, we calculated the mean effect from all instruments measuring symptoms directly related to the eligible illness, so that each study provided only one effect size for each treatment comparison. When trials included more than one relevant intervention compared with a single control, we allocated one-half the control sample to each comparison to avoid false precision. We evaluated for statistical heterogeneity using Cochrane’s Q and I^2^ statistics. An I^2^ of 0 percent indicates no observed heterogeneity, and larger values suggest increasing heterogeneity: 25 percent is interpreted as low, 50 percent as moderate, and ≥75 percent as high heterogeneity.38

### Levels of cCBT Support

We used subgroup analyses to explore potential sources of heterogeneity, including the level of support given with the intervention and the type of control group. We classified interventions into the following four mutually exclusive categories:

1. No support (cCBT-NS) interventions were designed to be standalone cCBT interventions. The participant was encouraged to go to a website and work through the cCBT program modules at an approximate rate of one per week. After beginning the intervention, no significant human support, feedback, or engagement was provided. However, participants may have received technical support for problems accessing or utilizing the program but not to explain material.
2. Supported (cCBT-S) interventions used a form of interaction involving a technician (nonlicensed staff) or clinician (licensed professional) regarding the content of the cCBT modules. Such support included feedback on the participant’s previous interactions with the program, and psychoeducation. This type of support was bidirectional but not in real time; that is, receipt of a communication from either party was delayed (not synchronous).
3. Live support (cCBT-LS) interventions involved real-time interactions with study technicians or clinicians, including phone sessions, a scheduled chat on internet forums, or instant messaging.
4. Adjunct to therapy (cCBT-AT) interventions employed a traditional, face-to-face therapy protocol as the primary intervention, with components of cCBT as part of the intervention but not the focus; the cCBT program was used to augment or reinforce the face-to-face session.

### Types of Control Groups

We classified control groups into three categories:

1. Waitlist control groups typically completed assessments with no study-related treatment provided while the cCBT arm was receiving treatment. The control group would then receive the intervention.
2. Treatment as usual control groups typically received a referral or had primary care physicians who received information on treating the symptoms or disorder that was the focus of the trial.
3. Attention/information control groups typically received supportive treatment or psychoeducation regarding the symptoms or disorder being targeted.

Because subgroup analyses involve indirect comparisons (across studies) and are susceptible to confounding, we considered these analyses to be hypothesis-generating. We used meta-regression analyses to test whether there was a significant relation between the proportion of patients completing all treatment modules and the treatment effect. We used Comprehensive Meta-Analysis (version 2.2.064) to calculate the summary SMD, and conduct meta-regression and subgroup analyses. Publication bias was assessed using findings from a ClinicalTrials.gov search. We included funnel plots when at least 10 studies were included in the analysis.

Where quantitative synthesis was not feasible (as for patient satisfaction and adherence outcomes), we analyzed the data qualitatively. We gave more weight to the evidence from higher quality studies with more precise estimates of effect. The qualitative syntheses focused on documenting and identifying patterns in efficacy and safety of the intervention across conditions and outcome categories. We also analyzed potential reasons for inconsistency in treatment effects across studies by evaluating differences in the study population, intervention, comparator, and outcome definitions.

## STRENGTH OF THE BODY OF EVIDENCE

In addition to rating the quality of individual studies, we evaluated the overall strength of evidence (SOE) for each KQ as described in the “Methods Guide.”34 In brief, this approach requires assessment of four domains: risk of bias, consistency, directness, and precision. These domains along with evidence for publication bias were considered qualitatively, and a summary rating of high, moderate, low, or insufficient SOE was assigned after discussion by two reviewers. The four-level rating scale consists of the following definitions:

- High—We are very confident that the true effect lies close to that of the estimate of the effect.
- Moderate—We are moderately confident in the effect estimate: The true effect is likely to be close to the estimate of the effect, but there is a possibility that it is substantially different.
- Low—Our confidence in the effect estimate is limited: The true effect may be substantially different from the estimate of the effect.
- Insufficient—Evidence on an outcome is absent or too weak, sparse, or inconsistent to estimate an effect.

When a rating of high, moderate, or low was not possible or was imprudent to make, a rating of insufficient was assigned.

## PEER REVIEW

A draft of the report was reviewed by technical experts and clinical leadership. A transcript of their comments and our responses is available in Appendix C.