# INTRODUCTION

Mental health disorders negatively affect an individual’s ability to perform basic daily activities, are associated with increased risk of morbidity and mortality, and impose a substantial economic burden on the U.S. healthcare system.1–3 Of the 5.2 million Veterans who received healthcare from Veterans Health Administration (VHA) in 2010, approximately 1.2 million received care for mental health needs.4 Consistent with these Veteran-specific data, national epidemiological studies have shown that mental health disorders are highly prevalent among adults in the United States, with the 12-month prevalence rates of mood disorders and anxiety disorders estimated to be 9.5 percent and 18.1 percent, respectively.5 Given the high rates of mental illness among Veterans returning from Iraq and Afghanistan, it is not surprising that the demand for mental health services in VHA has increased 132 percent since 2006.^4^ The most commonly diagnosed and treated disorders among Veterans receiving care at VHA include (1) adjustment reactions (e.g., posttraumatic stress disorder [PTSD]), (2) depressive disorders, (3) episodic mood disorders, (4) anxiety disorders (e.g., panic disorder, generalized anxiety disorder, phobias), and (5) substance abuse disorders. Unfortunately, a variety of logistical barriers prevent Veterans from accessing VHA mental healthcare, including distance and transportation challenges that hinder travel to and from appointments, challenges in arranging child care and spousal support, time constraints, and difficulty scheduling appointments.4

To address the growing need for mental health services and barriers to accessing these services, the Department of Defense and VHA launched the Integrated Mental Health Strategy (IMHS) in 2010. The IMHS consists of a series of 28 strategic actions designed to help both agencies better meet the unique mental health needs of military service members, Veterans, and their families. One strategic action involves creating a series of web-based self-help programs. Programs under this initiative leverage technology to enhance and expand the capacity of mental health treatment providers to deliver interventions through the use of health information technology and applications available for use on computer operating systems (e.g., desktop, laptop) and mobile operating systems (e.g., smartphones, tablets, personal digital assistant, portable media devices). Given that these services can be accessed anonymously, anytime, anywhere, and by multiple Veterans simultaneously, computer- and web-based services have the potential to surmount stigma along with geographical and financial barriers to accessing mental health treatment. In November 2012, “Moving Forward,” based on problem-solving therapy, was the first in this series to be released. Programs focusing on parenting and anger management are planned to be released in 2013, and additional programs for selected mental health disorders are under review.

Important considerations for interventions developed through the IMHS initiative include evaluation of the empirical evidence for an intervention, understanding the elements that make an intervention successful, and for whom and under what circumstances is an intervention effective. One approach about which a great deal is known is cognitive behavioral therapy (CBT). CBT is a structured, time-limited, present-focused approach to psychotherapy that helps patients learn and apply specific strategies to modify maladaptive thoughts and behaviors that contribute to distress. Originally developed for the treatment of depression,6,7 CBT has since been adapted for the treatment of anxiety disorders,8 substance use disorders,9 personality disorders,10 eating disorders,11 and severe mental illnesses, including bipolar disorder12 and schizophrenia.13 CBT is effective in treating mild, moderate, and severe mental health symptoms.14,15 Further, CBT is equally as effective as psychotropic medications in the short term and, for some conditions, is more effective than psychotropic medications in the long term.16

## COMPUTERIZED COGNITIVE BEHAVIORAL THERAPY

Although computer-based self-help programs grounded in CBT—which we refer to as computerized CBT (cCBT)—have generally been shown to produce significant reductions in depressive and anxiety symptoms, there is variation across studies in the implementation and effects of these interventions.17–19 Also, participation in such programs typically declines after the initial engagement, with reports of attrition higher than 50 percent in some studies.20–22 The availability of support via email, instant messaging, or phone contact with a therapist, coach, or peer specialist may mitigate attrition and improve treatment outcomes.19,23 However, it remains unclear how support-related factors (e.g., frequency of contact between patient and support provider, method and frequency of communication, optimal level of support provider training) influence treatment response to cCBT programs.

To support the development of cCBT self-help programs, the VA commissioned the Evidence-based Synthesis Program (ESP) to conduct a systematic review of the literature. Thus, our objectives in summarizing the results of randomized controlled trials (RCTs) that tested cCBT interventions were threefold. The first aim was to compare the effectiveness of cCBT with inactive controls. The second was to examine the influence of support-related factors on treatment outcomes including satisfaction, response, and completion. The third was to compare the effectiveness of cCBT with face-to-face CBT. Additional analyses and qualitative descriptions sought to explain critical components of effective cCBT interventions, identify gaps in the treatment literature, and generate hypotheses and ideas for future research studies.