# STUDY CHARACTERISTICS TABLES

Table D-1 Detailed study characteristics of cCBT interventions

Table D-2 Program components of cCBT interventions

Table D-3 General characteristics of cCBT interventions

Table D-4 Type and intensity of support in cCBT interventions

## ABBREVIATIONS USED IN APPENDIX D TABLES

Abbreviation: Term
AC: attention control
ACQ: Agoraphobic Cognitions Questionnaire
ADIS: Anxiety Disorder Interview Schedule
ASI: Anxiety Sensitivity index;
ATQ: Adult Temperament Questionnaire
BA: behavior activation
BAI: Beck Anxiety Inventory
BDI: Beck Depression Inventory
BSQ: Body Shape Questionnaire
BVS: Body Vigilance Scale
CBT: cognitive behavioral therapy
CBM: cognitive bias modification
cCBT: computerized cognitive behavioral therapy
cCBT-AT: cCBT adjunct to therapy
cCBT-LS: cCBT live support
cCBT-NS: cCBT no support
cCBT-S: cCBT supported
CES-D: Center for Epidemiologic Studies Depression scale
CIDI-SF: Composite International Diagnostic Interview-Short Form
CIS-R: Clinical Interview Schedule-Revised
CYL: Color Your Life
CWD: Coping With Depression
DASS: Depression Anxiety Stress Scale
DM: diabetes mellitus
DSM: Diagnostic and Statistical Manual for Mental Disorders
EOT: end of treatment
EQ5D: European Quality of Life scale, 5 dimensions
GAD: generalized anxiety disorder
GAD-7: Generalized Anxiety Disorder scale, 7 items
GHQ-12: General Health Questionnaire, 12 items
GP: general practitioner
HADS: Hospital Anxiety and Depression Scale
HMO: Health Maintenance Organization
HRQOL: health-related quality of life
IC: information control
ISG: internet support group
K10: Kessler Psychological Distress Scale
MADRS: Montgomery-Asberg Depression Scale
MADRS-S: Montgomery-Asberg Depression Rating Scale (self-rating version)
MDD: major depressive disorder
MINI: Mini-International Neuropsychiatric Interview
NA: not applicable
NR: not reported
PAID: Problem Areas in Diabetes scale
PCL: Posttraumatic Stress Disorder Checklist
PD: panic disorder
PDSS: Panic Disorder Severity Scale
PHQ-9: Patient Health Questionnaire, 9 items
PROQSY: Programmable Questionnaire System
PST: problem-solving therapy
PSWQ: Penn State Worry Questionnaire
PTSD-SS: Posttraumatic Stress Disorder Symptom Scale
QOLI: Quality of Life Inventory
RCT: randomized controlled trial
SCID: Structured Clinical Interview for DSM Disorders
SCL: Symptom Checklist
SD: standard deviation
SDS: Sheehan Disability Scale
SF-12: Short Form Health Survey, 12 items
S-STAI: Short State-Trait Anxiety Inventory
TAU: treatment as usual
WHODAS: World Health Organization Disability Assessment Schedule
WHOQOL-BREF: World Health Organization Quality of Life, shorter version
WL: waitlist
WSAS: Work and Social Adjustment Scale

## REFERENCES CITED IN APPENDIX D

1 Andersson G, Bergstrom J, Hollandare F, et al. Internet-based self-help for depression: randomised controlled trial. Br J Psychiatry. 2005;187:456-61. [pmid: 16260822].
2 Berger T, Hammerli K, Gubser N, et al. Internet-based treatment of depression: a randomized controlled trial comparing guided with unguided self-help. Cogn Behav Ther. 2011;40(4):251-66. [pmid: 22060248].
3 Carlbring P, Hagglund M, Luthstrom A, et al. Internet-based behavioral activation and acceptance-based treatment for depression: a randomized controlled trial. J Affect Disord. 2013;148(2–3):331-7. [pmid: 23357657].
4 Choi I, Zou J, Titov N, et al. Culturally attuned Internet treatment for depression amongst Chinese Australians: a randomised controlled trial. J Affect Disord. 2012;136(3):459-68. [pmid: 22177742].
5 Johansson R, Sjoberg E, Sjogren M, et al. Tailored vs. standardized internet-based cognitive behavior therapy for depression and comorbid symptoms: a randomized controlled trial. PLoS One. 2012;7(5):e36905. [pmid: 22615841].
6 Kessler D, Lewis G, Kaur S, et al. Therapist-delivered Internet psychotherapy for depression in primary care: a randomised controlled trial. Lancet. 2009;374(9690):628-34. [pmid: 19700005].
7 Perini S, Titov N, Andrews G. Clinician-assisted Internet-based treatment is effective for depression: randomized controlled trial. Aust N Z J Psychiatry. 2009;43(6):571-8. [pmid: 19440890].
8 Titov N, Andrews G, Davies M, et al. Internet treatment for depression: a randomized controlled trial comparing clinician vs. technician assistance. PLoS One. 2010;5(6):e10939. [pmid: 20544030].
9 Vernmark K, Lenndin J, Bjarehed J, et al. Internet administered guided self-help versus individualized e-mail therapy: A randomized trial of two versions of CBT for major depression. Behav Res Ther. 2010;48(5):368-76. [pmid: 20152960].
10 Williams AD, Blackwell SE, Mackenzie A, et al. Combining Imagination and Reason in the Treatment of Depression: A Randomized Controlled Trial of Internet-Based Cognitive-Bias Modification and Internet-CBT for Depression. J Consult Clin Psychol. 2013.
11 Wright JH, Wright AS, Albano AM, et al. Computer-assisted cognitive therapy for depression: maintaining efficacy while reducing therapist time. Am J Psychiatry. 2005;162(6):1158-64. [pmid: 15930065].
12 Clarke G, Reid E, Eubanks D, et al. Overcoming depression on the Internet (ODIN): a randomized controlled trial of an Internet depression skills intervention program. J Med Internet Res. 2002;4(3):E14. [pmid: 12554545].
13 de Graaf LE, Gerhards SA, Arntz A, et al. Clinical effectiveness of online computerised cognitive-behavioural therapy without support for depression in primary care: randomised trial. Br J Psychiatry. 2009;195(1):73-80. [pmid: 19567900].
14 Farrer L, Christensen H, Griffiths KM, et al. Internet-based CBT for depression with and without telephone tracking in a national helpline: randomised controlled trial. PLoS One. 2011;6(11):e28099. [pmid: 22140514].
15 Glozier N, Christensen H, Naismith S, et al. Internet-Delivered Cognitive Behavioural Therapy for Adults with Mild to Moderate Depression and High Cardiovascular Disease Risks: A Randomised Attention-Controlled Trial. PLoS One. 2013;8:3. Article Number: e59139.
16 Griffiths KM, Mackinnon AJ, Crisp DA, et al. The Effectiveness of an Online Support Group for Members of the Community with Depression: A Randomised Controlled Trial. PLoS One. 2012;7(12).
17 Hickie IB, Davenport TA, Luscombe GM, et al. Practitioner-supported delivery of internet-based cognitive behaviour therapy: evaluation of the feasibility of conducting a cluster randomised trial. Med J Aust. 2010;(11 Suppl):S31-5. [pmid: 20528705].
18 Levin W, Campbell DR, McGovern KB, et al. A computer-assisted depression intervention in primary care. Psychol Med. 2011;41(7):1373-83. [pmid: 20961474].
19 Lintvedt OK, Griffiths KM, Sorensen K, et al. Evaluating the effectiveness and efficacy of unguided internet-based self-help intervention for the prevention of depression: a randomized controlled trial. Clin Psychol Psychother. 2013;20(1):10-27. [pmid: 21887811].
20 Mackinnon A, Griffiths KM, Christensen H. Comparative randomised trial of online cognitive-behavioural therapy and an information website for depression: 12-month outcomes. Br J Psychiatry. 2008;192(2):130-4. [pmid: 18245031].
21 Moritz S, Schilling L, Hauschildt M, et al. A randomized controlled trial of internet-based therapy in depression. Behav Res Ther. 2012;50:513-21. [pmid: 22677231].
22 Spek V, Nyklicek I, Smits N, et al. Internet-based cognitive behavioural therapy for subthreshold depression in people over 50 years old: a randomized controlled clinical trial. Psychol Med. 2007;37(12):1797-806. [pmid: 17466110].
23 van Bastelaar KM, Pouwer F, Cuijpers P, et al. Web-based depression treatment for type 1 and type 2 diabetic patients: a randomized, controlled trial. Diabetes Care. 2011;34(2):320-5. [pmid: 21216855].
24 van der Zanden R, Kramer J, Gerrits R, et al. Effectiveness of an online group course for depression in adolescents and young adults: a randomized trial. J Med Internet Res. 2012;14(3):e86. [pmid: 22677437].
25 Wagner B, Horn AB, Andreas M. Internet-based versus face-to-face cognitive-behavioral intervention for depression: A randomized controlled non-inferiority trial. J Affect Disord. 2013.
26 Warmerdam L, van Straten A, Twisk J, et al. Internet-based treatment for adults with depressive symptoms: randomized controlled trial. J Med Internet Res. 2008;10(4):e44. [pmid: 19033149].
27 Newby JM, Mackenzie A, Williams AD, et al. Internet cognitive behavioural therapy for mixed anxiety and depression: a randomized controlled trial and evidence of effectiveness in primary care. Psychol Med. 2013:1-14.
28 Proudfoot J, Goldberg D, Mann A, et al. Computerized, interactive, multimedia cognitive-behavioural program for anxiety and depression in general practice. Psychol Med. 2003;33(2):217-27. [pmid: 12622301].
29 Proudfoot J, Ryden C, Everitt B, et al. Clinical efficacy of computerised cognitive-behavioural therapy for anxiety and depression in primary care: randomised controlled trial. Br J Psychiatry. 2004;185:46-54. [pmid: 15231555].
30 Andersson G, Paxling B, Roch-Norlund P, et al. Internet-based psychodynamic versus cognitive behavioral guided self-help for generalized anxiety disorder: a randomized controlled trial. Psychother Psychosom. 2012;81(6):344-55. [pmid: 22964540].
31 Paxling B, Almlov J, Dahlin M, et al. Guided internet-delivered cognitive behavior therapy for generalized anxiety disorder: a randomized controlled trial. Cogn Behav Ther. 2011;40(3):159-73. [pmid: 21770848].
32 Robinson E, Titov N, Andrews G, et al. Internet treatment for generalized anxiety disorder: a randomized controlled trial comparing clinician vs. technician assistance. PLoS One. 2010;5(6):e10942. [pmid: 20532167].
33 Titov N, Andrews G, Robinson E, et al. Clinician-assisted Internet-based treatment is effective for generalized anxiety disorder: Randomized controlled trial. Aust N Z J Psychiatry. 2009;43(10):905-912.
34 Bergstrom J, Andersson G, Ljotsson B, et al. Internet-versus group-administered cognitive behaviour therapy for panic disorder in a psychiatric setting: a randomised trial. BMC Psychiatry. 2010;10:54. [pmid: 20598127].
35 Carlbring P, Westling BE, Ljungstrand P, et al. Treatment of panic disorder via the Internet: A randomized trial of a self-help program. Behav Ther. 2001;32(4):751-764.
36 Carlbring P, Nilsson-Ihrfelt E, Waara J, et al. Treatment of panic disorder: live therapy vs. self-help via the Internet. Behav Res Ther. 2005;43(10):1321-33. [pmid: 16086983].
37 Carlbring P, Bohman S, Brunt S, et al. Remote treatment of panic disorder: a randomized trial of internet-based cognitive behavior therapy supplemented with telephone calls. Am J Psychiatry. 2006;163(12):2119-25. [pmid: 17151163].
38 Kenardy JA, Dow MG, Johnston DW, et al. A comparison of delivery methods of cognitive-behavioral therapy for panic disorder: an international multicenter trial. J Consult Clin Psychol. 2003;71(6):1068-75. [pmid: 14622082].
39 Kiropoulos LA, Klein B, Austin DW, et al. Is internet-based CBT for panic disorder and agoraphobia as effective as face-to-face CBT?. J Anxiety Disord. 2008;22(8):1273-84. [pmid: 18289829].
40 Klein B, Richards JC, Austin DW. Efficacy of internet therapy for panic disorder. J Behav Ther Exp Psychiatry. 2006;37(3):213-38. [pmid: 16126161].
41 Richards JC, Klein B, Austin DW. Internet cognitive behavioural therapy for panic disorder: Does the inclusion of stress management information improve end-state functioning?. Clinical Psychologist. 2006;10(1):2-15.
42 Silfvernagel K, Carlbring P, Kabo J, et al. Individually tailored internet-based treatment for young adults and adults with panic attacks: randomized controlled trial. J Med Internet Res. 2012;14(3):e65. [pmid: 22732098].
43 Wims E, Titov N, Andrews G, et al. Clinician-assisted Internet-based treatment is effective for panic: A randomized controlled trial. Aust N Z J Psychiatry. 2010;44(7):599-607. [pmid: 20560847].
44 Litz BT, Engel CC, Bryant RA, et al. A randomized, controlled proof-of-concept trial of an Internet-based, therapist-assisted self-management treatment for posttraumatic stress disorder. Am J Psychiatry. 2007;164(11):1676-83. [pmid: 17974932].
45 Spence J, Titov N, Dear BF, et al. Randomized controlled trial of Internet-delivered cognitive behavioral therapy for posttraumatic stress disorder. Depress Anxiety. 2011;28(7):541-50. [pmid: 21721073].
46 Kenardy J, McCafferty K, Rosa V. Internet-delivered indicated prevention for anxiety disorders: Six-month follow-up. Clinical Psychologist. 2006;10(1):39-42.
47 Ruwaard J, Broeksteeg J, Schrieken B, et al. Web-based therapist-assisted cognitive behavioral treatment of panic symptoms: a randomized controlled trial with a three-year follow-up. J Anxiety Disord. 2010:387-96. [pmid: 20227241].