# PEER REVIEW COMMENTS

Reviewer | Comment | Response
Question 1: Are the objectives, scope, and methods for this review clearly described?
1 | Yes. | Thank you.
2 | Yes, the objectives, scope and methods were clearly described. | Thank you.
3 | Overall, the objectives, scope, and methods are clear, and it appears that the investigators’ approach was thorough and descriptive. Below are some specific comments that hopefully will be helpful in finalizing the report.; 1. Many studies excluded patients with severe symptoms – this is an important limitation given that the mean baseline scores on symptom measures of Veterans receiving CBT and other evidence-based psychotherapies are typically in the severe range. This may affect the generalizability of the findings to the Veteran patient population. At minimum, recommend that this be emphasized and included as a limitation in the executive summary.; 2. Similarly, studies examined generally included few older individuals (who represent the majority of the Veteran patient population) and seemingly included primarily individuals with significant interest and experience using computers and/or the Internet. While this is appropriately noted in the discussion of the findings, I think the implications of this should be further emphasized. In fact, it appears that no one truly older individual, using the conventional definition for this age group (65+), was included in any of the studies.; 3. In addition, examinations of CBT with Veterans, specifically, have shown that the therapeutic alliance (emphasized in in-person VA CBT protocols) is significantly related to outcome – and this relationship is even greater among older Veterans. This seems at least worthy of mention.; 4. There is limited mention of to what extent and how the quality of studies was considered. Were only studies of certain quality included and how many studies were excluded?; 5. Psychotropic medication was allowed in 75 percent of the studies examined – if individuals were newer to treatment and not receiving psychotropic medication for some time, improvements could have been due to the psychotropic medication. Were studies excluded if this potential confound was not addressed? If not, this should be noted as a limitation; 6. I do not recommend combining studies examining PTSD and anxiety disorder and reporting the effect size across these studies.; 7. The method of calculating the SMD by dividing the result by the pooled standard deviations of the two groups is considered by some to be a less conservative method for calculating the effect size. | 1. We agree that this issue is important for applicability to the Veteran population. We have given this point greater prominence (see pages 56–58). We think that CBT delivered via computer might be well suited to patients seen in primary care, who typically have mild to moderate severity. We agree that the evidence does not directly address patients with severe symptoms and that these patients might be served better by a clinic-based therapist in case of the need for crisis intervention.; 2. We agree that this is an important issue related to applicability of the findings. Older adults may respond differentially to treatment compared with younger adults and may have different facility with or different response to computerized CBT. We have emphasized the absence of studies in older adults in the Executive Summary and Discussion.; 3. This is an important consideration, and we think our analysis of the level of human support for cCBT is relevant to this question. As a result, we have added some discussion of the potentially important role of therapeutic alliance to the section of the Clinical and Policy Implications that addresses cCBT support.; 4. Otherwise eligible studies were included without regard to the quality rating. Quality ratings are detailed in Appendix B and provided for each study in Appendix D. Quality rating (Risk of Bias) is included in the qualitative description of the studies and considered explicitly in the SOE rating (see Methods section).; 5. With the literature from the updated search added, this falls to 70 percent. The reviewer makes a good point; however, all studies that allow for concurrent medication required that patients be on a stable dose for a period of time prior to study enrollment or the patients were excluded. This clarification has been added.; 6. We did not combine studies to compute a summary estimate of effect for studies examining PTSD and anxiety disorders. We combined major depressive disorder and depressive symptoms.; 7. We acknowledge that there are different approaches to calculating the SMD, including approaches that correct for small sample sizes. We conducted a sensitivity analysis and found little impact on the estimates (≤0.01SMD) across methods.
4 | Yes. The authors prepared a very clear and comprehensive review of the topic. | Thank you.
Question 2: Is there any indication of bias in our synthesis of the evidence?
1 | No. The systematic review was clearly well done and free of bias, following all standards in existence regarding transparency in review. | Thank you.
2 | Yes, bias was examined and was minimal | Thank you.
3 | No. | Thank you.
4 | No. | Thank you.
Question 3: Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked?
1 | No. The internet based and computer based projects are all well represented. You will need to do a new review in a few years to include apps and mobile mental health games (once data from the Harnessing Technologies RFA are published). | Thank you for the suggestion.
2 | Yes. The authors refer to additional studies that will be included in the manuscript and it was not clear why these studies were not included in the current report or at least at a minimum, discussion provided as to whether these studies influence outcomes reported in anyway | All but one of the additional eight studies referred to were published in 2013 and found when we updated the literature search on August 30, 2013. We have rerun all analyses and updated all outcomes affected by these new studies.
3 | No. None identified. | Thank you.
4 | No. | Thank you.
Question 4: Please write additional suggestions or comments below. If applicable, please indicate the page and line numbers from the draft report.
1 | The review as comprehensive, I have no other comments | Thank you.
2 | May highlight in the review articles that specifically included veterans. In general, the report was clearly written, justifications for decisions were sound, and the report addresses an important topic. Page 34 – 35 the x axis changes from figure 7 to figure 8. Helpful to ensure that the labels are consistent for all graphs Worth considering for the paper, the role of adherence. Did interventions that have higher rates of intervention adherence result in better outcomes? What aspects of treatment intervention adherence were helpful? | Our review of the literature found only one article specifically addressing Veterans. This is given special emphasis in the report. We chose the X axis such that the effect estimate and 95% CI for most studies is included. This means the X axis is ± 2.0 for almost all graphs but in selected cases had to be modified to meet our graphical display criteria. We conducted a meta-regression analysis for the subset of studies reporting proportion of patients completing all modules. There was no association with the estimate of treatment effect. With regard to the relationship between the treatment intervention and adherence, there was not sufficient detail or number of studies reporting these characteristics to evaluate this association.
3 | 1. Electronic CBT (eCBT) is not typically the standard term used for referring to computerized CBT. This is more commonly referred to as “computer-assisted”, “computer-administered”, “computerized”, “computer-based”, etc. Further, “eCBT” is the name of a specific, proprietary phone app for CBT for depression.; 2. The low completion rate observed appears to be significantly lower than that for in-person CBT (e.g., Eftekhari et al., 2013; Karlin et al., 2012).; 3. “Mental health disorders” should read “mental disorders.”; 4. I appreciate the investigators’ focus on the relationship between eCBT support and patient outcomes. The issue of therapist support has been an important one in this area, as it has appeared that level of therapist supported is positively associated with outcomes and adherence. As noted by the investigators, the “supported” category included a broad range of support types, making it difficult to fully examine this question. Additional, systematic research examining this issue would be worthwhile. However, the current investigation appears to confirm previous findings.; 5. It would likely be useful to report the adherence/completion rate by condition cluster, in addition to or place of the overall rate across diagnostic areas. Looking at the rates reported for each individual study, there appears to be very wide variability. Is there evidence of why this was? Presumably, this may be related to level of therapist involvement, as some previous research had suggested. Thank you for the opportunity to review this report. | 1. We have revised the report to use the term computerized CBT (cCBT).; 2. We agree and have noted in the summary of evidence that the adherence rates were relatively low compared with those observed for in-person therapy. In addition, improved adherence/completion was identified as a future direction for cCBT.; 3. We have made the correction.; 4. Acknowledged; thank you for your comment.; 5. Thank you for this suggestion. We found the proportion completing all modules does vary by condition cluster. We have added this information to the results and discussion of adherence. There were not sufficient studies reporting adherence to the control group within condition clusters to examine an association between therapist support and adherence.
4 | Very minor comments:; 1. There was a possible typo on page 24, should be 218 excluded rather than 220 to get numbers to add up; 2. In cases when there were multiple measures in the same study, the authors chose to calculate the mean effect from all instruments (Page 21). While this sounds reasonable to me, I wonder if the authors chose the same approach if a study pre-specified a primary outcome. | 1. We have updated and corrected the numbers in the literature flow.; 2. We compared the authors’ prespecified primary measure(s) to the outcome measures included in our analyses. In almost all instances there was perfect agreement.
Optional Dissemination and Implementation Questions
Question 5: Are there any clinical performance measures, programs, quality improvement measures, patient care services, or conferences that will be directly affected by this report? If so, please provide detail.
1 | All I am aware of is the National Center for PTSD and their work around mobile mental health – they would benefit from this report. Worthwhile at some point to do a review for older adults and technology interventions, given the aging of the veteran population | Thank you for the suggestion.
2 | If issues related to IT and confidentiality are addressed in the VA, the report may be able to influence policy by providing electronic CBT to veterans to address the continued lack of adequate mental health providers | Thank you for the suggestion about IT. This has been discussed in a little more detail in the revised discussion section.
3 | No comments | Thank you.
4 | No comments | Thank you.
Question 6: Please provide any recommendations on how this report can be revised to more directly address or assist implementation needs.
1 | Maybe more on how these data affect older populations. | Thank you for the suggestion.
2 | Further clarify what the recommendations the VA can use to implement electronic CBT. A recommendation for a comparator may be examining outcomes of individuals who can select receiving cognitive behavioral interventions via life person, or computer based. In reality, this is likely the way these programs would likely be introduced. Consider providing more comment on the resources and staffing of the use of ECBT? If there are a limited of mental health clinicians, is using computer based CBI a way to offset these challenges? | Thank you, we have provided further explanation in the Discussion section of the report.
3 | No comments | Thank you.
4 | No comments | Thank you.
Question 7: Please provide us with contact details of any additional individuals/stakeholders who should be made aware of this report.
1 | David Mohr at NorthWestern | Thank you for the suggestion.
2 | No comments | Thank you.
3 | No comments | Thank you.
4 | No comments | Thank you.