# SEARCH STRATEGIES

Table A-1 Search strategy for PubMed (August 30, 2013)

Set # | Terms | Results
1 | “Behavior Therapy”[Mesh] OR ((behavior[tiab] OR behaviour[tiab]) AND (therapy [tiab] OR therapies[tiab)) OR Aversive[tiab] OR Biofeedback[tiab] OR Feedback[tiab] OR Neurofeedback[tiab] OR Desensitization[tiab] OR Virtual Reality[tiab] OR Exposure[tiab] OR Relaxation[tiab] OR Meditation[tiab] OR chronotherapy[tiab] OR commitment[tiab] OR dialectical[tiab] OR “Cognitive Therapy”[Mesh] OR ((cognitive[tiab] OR cognition[tiab]) AND (therapy[tiab] OR therapies[tiab])) OR “Psychotherapy, Brief”[Mesh] OR ((brief[tiab] OR short-term[tiab]) AND (psychotherapy[tiab] OR psychotherapies[tiab])) | 784265
2 | “Depressive Disorder”[Mesh] OR “Dysthymic Disorder”[Mesh] OR “Adjustment Disorders”[Mesh] OR “Stress Disorders, Post-Traumatic”[Mesh] OR Dysthymia[tiab] OR Minor Depression[tiab] OR Adjustment disorder[tiab] OR ptsd[tiab] OR generalized anxiety disorder[tiab] OR Depression[Mesh] OR Anxiety[Mesh:noexp] OR “Anxiety Disorders”[Mesh:noexp] OR “Panic Disorder”[Mesh] OR “Obsessive-Compulsive Disorder”[Mesh] OR anxiety disorder nos[tiab] OR mixed anxiety[tiab] OR subthreshold depression[tiab] OR minor depression[tiab] OR subsyndromal depression[tiab] OR panic[Mesh] | 213813
3 | (Computer-assisted Psychotherapy[tiab] OR Computerized Cognitive Behavioral Therapy[tiab] OR Low Intensity[tiab]) OR (“Internet”[Mesh] OR internet[tiab] OR web[tiab] OR social-media[tiab] OR “Therapy, Computer-Assisted”[Mesh]) OR (online[tiab] OR computer[tiab] OR computers[tiab] OR computerized[tiab] OR mobile[tiab] OR smartphone[tiab] OR smartphones[tiab] OR tablet[tiab] OR tablets[tiab] OR self-paced[tiab] OR computers[Mesh]) | 456239
4 | (randomized controlled trial[pt] OR controlled clinical trial[pt] OR clinical trial[pt] OR randomized[tiab] OR randomised[tiab] OR randomization[tiab] OR randomisation[tiab] OR control[tiab] OR randomly[tiab] OR trial[tiab] OR groups[tiab]) NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp]) | 3151494
5 | #1 AND #2 AND #3 AND #4 Filters: Publication date from 1990/01/01 to 2013/12/31; English | 442