# REFERENCES

1 Assendelft WJ, Morton SC, Yu EI, Suttorp MJ, Shekelle PG. Spinal Manipulative Therapy for Low Back Pain: A Meta-Analysis of Effectiveness Relative to Other Therapies. Annals of Internal Medicine. 2003(11):871–881. http://onlinelibrary.wiley.com/o/cochrane/cldare/articles/DARE-12003008464/frame.html.
2 Rubinstein SM, Terwee CB, Assendelft WJ, Boer MR, Tulder MW. Spinal manipulative therapy for acute low back pain: an update of the Cochrane review (Structured abstract). Spine. 2013(3):E158–e177. http://onlinelibrary.wiley.com/o/cochrane/cldare/articles/DARE-12013013786/frame.html.23169072
3 Cherkin DC, Deyo RA, Battie M, Street J, Barlow W. A comparison of physical therapy, chiropractic manipulation, and provision of an educational booklet for the treatment of patients with low back pain. N Engl J Med. Oct 8 1998;339(15):1021–1029.9761803
4 Hancock MJ, Maher CG, Latimer J, . Assessment of diclofenac or spinal manipulative therapy, or both, in addition to recommended first-line treatment for acute low back pain: a randomised controlled trial. Lancet. Nov 10 2007;370(9599):1638–1643.17993364
5 van Tulder MW, Suttorp M, Morton S, Bouter LM, Shekelle P. Empirical evidence of an association between internal validity and effect size in randomized controlled trials of low-back pain. Spine (Phila Pa 1976). Jul 15 2009;34(16):1685–1692.19770609
6 IntHout J, Ioannidis JP, Borm GF. The Hartung-Knapp-Sidik-Jonkman method for random effects meta-analysis is straightforward and considerably outperforms the standard DerSimonian-Laird method. BMC medical research methodology. 2014;14(1):25.24548571
7 Sánchez-Meca J, Marín-Martínez F. Confidence intervals for the overall effect size in random-effects meta-analysis. Psychological Methods. 2008;13(1):31.18331152
8 Higgins JP, Thompson SG, Deeks JJ, Altman DG. Measuring inconsistency in meta-analyses. BMJ: British Medical Journal. 2003;327(7414):557.12958120
9 StataCorp. Stata Statistical Software: Release 12. College Station, TX: StataCorp LP;2011.
10 Begg CB, Mazumdar M. Operating characteristics of a rank correlation test for publication bias. Biometrics. 1994;50:1088–1101.7786990
11 Egger M, Smith GD, Schneider M, Minder C. Bias in meta-analysis detected by a simple, graphical test. BMJ. 1997;315(7109):629–634.9310563
12 Godfrey CM, Morgan PP, Schatzker J. A randomized trial of manipulation for low-back pain in a medical setting. Spine (Phila Pa 1976). Apr 1984;9(3):301–304.6233718
13 Hallegraeff JM, de Greef M, Winters JC, Lucas C. Manipulative therapy and clinical prediction criteria in treatment of acute nonspecific low back pain. Percept Mot Skills. Feb 2009;108(1):196–208.19425461
14 Rubinstein Sidney M, Terwee Caroline B, Assendelft Willem JJ, de Boer Michiel R, van Tulder Maurits W. Spinal manipulative therapy for acute low-back pain. Cochrane Database of Systematic Reviews 2012(9). http://onlinelibrary.wiley.com/doi/10.1002/14651858.CD008880.pub2/abstract.
15 Olsen MF, Bjerre, E, Hansen, M. D., Hilden, J., Landler, N.E., Tendal, B., & Hróbjartsson, A.. Pain relief that matters to patients: systematic review of empirical studies assessing the minimum clinically important difference in acute pain. BMC Medicine 2017;15(35).
16 GRADE working group. 2014; http://www.gradeworkinggroup.org/. Accessed 09/25/15.
17 Blomberg S, Hallin G, Grann K, Berg E, Sennerby U Manual therapy with steroid injections--a new approach to treatment of low back pain. A controlled multicenter trial with an evaluation by orthopedic surgeons. Spine (Phila Pa 1976). Mar 1 1994;19(5):569–577.8184352
18 Blomberg S, Svardsudd K, Mildenberger F A controlled, multicentre trial of manual therapy in low-back pain. Initial status, sick-leave and pain score during follow-up. Scand J Prim Health Care. Sep 1992;10(3):170–178.1410946
19 Blomberg S, Svardsudd K, Tibblin G Manual therapy with steroid injections in low-back pain. Improvement of quality of life in a controlled trial with four months’ follow-up. Scand J Prim Health Care. Jun 1993;11(2):83–90.8356370
20 Blomberg S, Svardsudd K, Tibblin G A randomized study of manual therapy with steroid injections in low-back pain. Telephone interview follow-up of pain, disability, recovery and drug consumption. Eur Spine J. 1994;3(5):246–254.7866845
21 Blomberg S, Tibblin G A controlled, multicentre trial of manual therapy with steroid injections in low-back pain: functional variables, side effects and complications during four months follow-up. Clinical Rehabilitation. 1993;7(1):49–62.
22 Grunnesjo MI, Bogefeldt JP, Svardsudd KF, Blomberg SI A randomized controlled clinical trial of stay-active care versus manual therapy in addition to stay-active care: functional variables and pain. J Manipulative Physiol Ther. Sep 2004;27(7):431–441.15389174
23 Grunnesjö MI, Bogefeldt JP, Blomberg SI, Strender LE, Svärdsudd KF A randomized controlled trial of the effects of muscle stretching, manual therapy and steroid injections in addition to ‘stay active’ care on health-related quality of life in acute or subacute low back pain. Clinical rehabilitation. 2011;25(11):999–1010. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/578/CN-00865578/frame.html.21831926
24 Bogefeldt J, Grunnesjo MI, Svardsudd K, Blomberg S Sick leave reductions from a comprehensive manual therapy programme for low back pain: the Gotland Low Back Pain Study. Clin Rehabil. Jun 2008;22(6):529–541.18511533
25 Bergquist-Ullman M, Larsson U Acute low back pain in industry. A controlled prospective study with special reference to therapy and confounding factors. Acta Orthop Scand. 1977(170):1–117.
26 Childs JD, Fritz JM, Flynn TW, . A clinical prediction rule to identify patients with low back pain most likely to benefit from spinal manipulation: a validation study. Ann Intern Med. Dec 21 2004;141(12):920–928.15611489
27 Cramer GD, Humphreys CR, Hondras MA, McGregor M, Triano JJ The Hmax/Mmax ratio as an outcome measure for acute low back pain. J Manipulative Physiol Ther. Jan 1993;16(1):7–13.8423429
28 Cruser A, Maurer D, Hensel K, Brown SK, White K, Stoll ST A randomized, controlled trial of osteopathic manipulative treatment for acute low back pain in active duty military personnel. Journal of manual & manipulative therapy. 2012;20(1):5–15. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/708/CN-00897708/frame.html.23372389
29 Delitto A, Cibulka MT, Erhard RE, Bowling RW, Tenhula JA Evidence for use of an extension-mobilization category in acute low back syndrome: a prescriptive validation pilot study. Phys Ther. Apr 1993;73(4):216–222; discussion 223–218.8456141
30 Erhard RE, Delitto A, Cibulka MT Relative effectiveness of an extension program and a combined program of manipulation and flexion and extension exercises in patients with acute low back syndrome. Phys Ther. Dec 1994;74(12):1093–1100.7991650
31 Farrell JP, Twomey LT Acute low back pain. Comparison of two conservative treatment approaches. Med J Aust. Feb 20 1982;1(4):160–164.6210835
32 Fritz JM, Magel JS, McFadden M, . Early physical therapy vs usual care in patients with recent-onset low back pain: A randomized clinical trial. JAMA - Journal of the American Medical Association. 13 2015;314(14):1459–1467.26461996
33 Glover JR, Morris JG, Khosla T Back pain: a randomized clinical trial of rotational manipulation of the trunk. Br J Ind Med. Jan 1974;31(1):59–64.4274488
34 Goertz CM, Long CR, Hondras MA, . Adding chiropractic manipulative therapy to standard medical care for patients with acute low back pain: results of a pragmatic randomized comparative effectiveness study. Spine. 2013;38(8):627–634. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/298/CN-00967298/frame.html.23060056
35 Hadler NM, Curtis P, Gillings DB, Stinnett S A benefit of spinal manipulation as adjunctive therapy for acute low-back pain: a stratified controlled trial. Spine (Phila Pa 1976). Sep 1987;12(7):702–706.2961085
36 Heymann WJ, Schloemer P, Timm J, Muehlbauer B Spinal high-velocity low amplitude manipulation in acute nonspecific low back pain: a double-blinded randomized controlled trial in comparison with diclofenac and placebo. Spine. 2013;38(7):540–548. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/716/CN-00878716/frame.html.23026869
37 Hoiriis KT, Pfleger B, McDuffie FC, . A randomized clinical trial comparing chiropractic adjustments to muscle relaxants for subacute low back pain. J Manipulative Physiol Ther. Jul–Aug 2004;27(6):388–398.15319761
38 Juni P, Battaglia M, Nuesch E, . A randomised controlled trial of spinal manipulative therapy in acute low back pain. Ann Rheum Dis. Sep 2009;68(9):1420–1427.18775942
39 MacDonald RS, Bell CM An open controlled assessment of osteopathic manipulation in nonspecific low-back pain. Spine (Phila Pa 1976). May 1990;15(5):364–370.2141951
40 Morton JE Manipulation in the treatment of acute low back pain. Journal of Manual & Manipulative Therapy. 1999;7(4):182–189.
41 Postacchini F, Facchini M, Palieri P Efficacy of various forms of conservative treatment in low back pain: a comparative study. Neuro-orthopedics. 1988;6(1):28–35.
42 Rasmussen G Manipulation in treatment of low back pain: a randomized clinical trial. Man Med. 1979;1:8–10.
43 Skargren EI, Carlsson PG, Oberg BE One-year follow-up comparison of the cost and effectiveness of chiropractic and physiotherapy as primary management for back pain. Subgroup analysis, recurrence, and additional health care utilization. Spine (Phila Pa 1976). Sep 1 1998;23(17):1875–1883; discussion 1884.9762745
44 Waterworth RF, Hunter IA An open study of diflunisal, conservative and manipulative therapy in the management of acute mechanical low back pain. N Z Med J. May 22 1985;98(779):372–375.3157894
45 Roelofs PD, Deyo RA, Koes BW, Scholten RJ, van Tulder MW Nonsteroidal anti-inflammatory drugs for low back pain: an updated Cochrane review. Spine (Phila Pa 1976). Jul 15 2008;33(16):1766–1774.18580547
46 Cherkin DC, Deyo RA, Street JH, Hunt M, Barlow W Pitfalls of patient education. Limited success of a program for back pain in primary care. Spine (Phila Pa 1976). Feb 1 1996;21(3):345–355.8742212
47 Machado GC, Maher CG, Ferreira PH, . Efficacy and safety of paracetamol for spinal pain and osteoarthritis: systematic review and meta-analysis of randomised placebo controlled trials. BMJ. 2015;350:h1225.25828856
48 Flynn T, Fritz J, Whitman J, . A clinical prediction rule for classifying patients with low back pain who demonstrate short-term improvement with spinal manipulation. Spine (Phila Pa 1976). Dec 15 2002;27(24):2835–2843.12486357
49 Hancock MJ, Maher CG, Latimer J, Herbert RD, McAuley JH Independent evaluation of a clinical prediction rule for spinal manipulative therapy: a randomised controlled trial. Eur Spine J. Jul 2008;17(7):936–943.18427840
50 Cleland JA, Fritz JM, Kulig K, . Comparison of the effectiveness of three manual physical therapy techniques in a subgroup of patients with low back pain who satisfy a clinical prediction rule: a randomized clinical trial. Spine (Phila Pa 1976). Dec 1 2009;34(25):2720–2729.19940729
51 Learman K, Showalter C, O’Halloran B, Donaldson M, Cook C No Differences in Outcomes in People with Low Back Pain Who Met the Clinical Prediction Rule for Lumbar Spine Manipulation When a Pragmatic Non-thrust Manipulation Was Used as the Comparator. Physiotherapy Canada. 2014;66(4):359–366.25922557
52 Schenk R, Dionne C, Simon C, Johnson R Effectiveness of mechanical diagnosis and therapy in patients with back pain who meet a clinical prediction rule for spinal manipulation. Journal of manual & manipulative therapy. 2012;20(1):43–49. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/754/CN-01018754/frame.html.23372393
53 Mathews JA, Mills SB, Jenkins VM, . Back pain and sciatica: controlled trials of manipulation, traction, sclerosant and epidural injections. Br J Rheumatol. Dec 1987;26(6):416–423.2961394
54 Mathews W, Morkel M, Mathews J Manipulation and traction for lumbago and sciatica: physiotherapeutic techniques used in two controlled trials. Physiotherapy Theory and Practice. 1988;4(4):201–206.
55 Santilli V, Beghi E, Finucci S Chiropractic manipulation in the treatment of acute back pain and sciatica with disc protrusion: a randomized double-blind clinical trial of active and simulated spinal manipulations. Spine J. Mar–Apr 2006;6(2):131–137.16517383
56 Paanalahti K, Holm LW, Nordin M, Asker M, Lyander J, Skillgate E Adverse events after manual therapy among patients seeking care for neck and/or back pain: a randomized controlled trial. BMC Musculoskeletal Disorders. 2014;15:77.24618345
57 Barrett AJ, Breen AC Adverse effects of spinal manipulation. J R Soc Med. May 2000;93(5):258–259.10884771
58 Cagnie B, Vinck E, Beernaert A, Cambier D How common are side effects of spinal manipulation and can these side effects be predicted? Man Ther. Aug 2004;9(3):151–156.15245709
59 Leboeuf-Yde C, Hennius B, Rudberg E, Leufvenmark P, Thunman M Side effects of chiropractic treatment: a prospective study. J Manipulative Physiol Ther. Oct 1997;20(8):511–515.9345679
60 Rubinstein SM, Leboeuf-Yde C, Knol DL, de Koekkoek TE, Pfeifle CE, van Tulder MW Predictors of adverse events following chiropractic care for patients with neck pain. Journal of Manipulative and Physiological Therapeutics. 2008;31(2):94–103.18328935
61 Senstad O, Leboeuf-Yde C, Borchgrevink C Frequency and characteristics of side effects of spinal manipulative therapy. Spine (Phila Pa 1976). Feb 15 1997;22(4):435–440; discussion 440–431.9055373
62 Maiers M, Evans R, Hartvigsen J, Schulz C, Bronfort G Adverse events among seniors receiving spinal manipulation and exercise in a randomized clinical trial. Manual Therapy. 1 2015;20(2):335–341.25454683
63 Walker BF, Hebert JJ, Stomski NJ, . Outcomes of usual chiropractic. The OUCH randomized controlled trial of adverse events. Spine. Sep 15 2013;38(20):1723–1729.23778372
64 Ernst E Ophthalmological adverse effects of (chiropractic) upper spinal manipulation: evidence from recent case reports (Structured abstract). Acta Ophthalmologica Scandinavica. 2005;83(5):581–585. http://onlinelibrary.wiley.com/o/cochrane/cldare/articles/DARE-12005004755/frame.html.16187996
65 Ernst E Deaths after chiropractic: a review of published cases (Provisional abstract). International Journal of Clinical Practice. 2010;64(8):1162–1165. http://onlinelibrary.wiley.com/o/cochrane/cldare/articles/DARE-12011007078/frame.html.20642715
66 Oliphant D Safety of spinal manipulation in the treatment of lumbar disk herniations: a systematic review and risk assessment (Provisional abstract). Journal of Manipulative and Physiological Therapeutics. 2004;27(3):197–210. http://onlinelibrary.wiley.com/o/cochrane/cldare/articles/DARE-12004001048/frame.html.15129202
67 Hebert JJ, Stomski NJ, French SD, Rubinstein SM Serious adverse events and spinal manipulative therapy of the low back region: a systematic review of cases (Provisional abstract). Journal of Manipulative and Physiological Therapeutics. 2013(4):epub. http://onlinelibrary.wiley.com/o/cochrane/cldare/articles/DARE-12013036142/frame.html.
68 Stevinson C, Ernst E Risks associated with spinal manipulation (Structured abstract). American Journal of Medicine. 2002(7):566–571. http://onlinelibrary.wiley.com/o/cochrane/cldare/articles/DARE-12002001305/frame.html.12015249
69 Carlesso LC, Gross AR, Santaguida PL, Burnie S, Voth S, Sadi J Adverse events associated with the use of cervical manipulation and mobilization for the treatment of neck pain in adults: a systematic review (Provisional abstract). Manual Therapy. 2010(5):434–444. http://onlinelibrary.wiley.com/o/cochrane/cldare/articles/DARE-12010006882/frame.html.20227325
70 Chung CL, Cote P, Stern P, L’Esperance G The association between cervical spine manipulation and carotid artery dissection: a systematic review of the literature (Provisional abstract). Journal of Manipulative and Physiological Therapeutics 2014(4). http://onlinelibrary.wiley.com/o/cochrane/cldare/articles/DARE-12014005028/frame.html.
71 Ernst E Manipulation of the cervical spine: a systematic review of case reports of serious adverse events, 1995 – 2001 (Structured abstract). Medical Journal of Australia. 2002(8):376–380. http://onlinelibrary.wiley.com/o/cochrane/cldare/articles/DARE-12002001060/frame.html.12041633
72 Walker BF, Hebert JJ, Stomski NJ, Losco B, French SD Short-term usual chiropractic care for spinal pain: a randomized controlled trial. Spine. 2013;38(24):2071–2078. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/967/CN-00914967/frame.html.24026159
73 Kosloff TM, Elton D, Tao J, Bannister WM Chiropractic care and the risk of vertebrobasilar stroke: results of a case-control study in U.S. commercial and Medicare Advantage populations. Chiropr Man Therap. 2015;23:19.
74 Whedon JM, Mackenzie TA, Phillips RB, Lurie JD Risk of Traumatic Injury Associated With Chiropractic Spinal Manipulation in Medicare Part B Beneficiaries Aged 66 to 99 Years. Spine. 2015;40(4):264–270.25494315
75 Cassidy JD, Boyle E, Côté P, . Risk of vertebrobasilar stroke and chiropractic care: results of a population-based case-control and case-crossover study. Journal of Manipulative and Physiological Therapeutics. 2009;32(2):S201–S208.19251066
76 Nielsen SM, Tarp S, Christensen R, Bliddal H, Klokker L, Henriksen M The risk associated with spinal manipulation: an overview of reviews. Syst Rev. Mar 24 2017;6(1):64.28340595
77 Rhee Y, Taitel MS, Walker DR, Lau DT Narcotic drug use among patients with lower back pain in employer health plans: a retrospective analysis of risk factors and health care services. Clinical therapeutics. 2007;29(11):2603–2612.18164925
78 Vogt MT, Kwoh CK, Cope DK, Osial TA, Culyba M, Starz TW Analgesic usage for low back pain: impact on health care costs and service use. Spine. 2005;30(9):1075–1081.15864162
79 Franklin GM, Rahman EA, Turner JA, Daniell WE, Fulton-Kehoe D Opioid use for chronic low back pain: A prospective, population-based study among injured workers in Washington state, 2002–2005. The Clinical journal of pain. 2009;25(9):743–751.19851153
80 Allen H, Wright M, Craig T, . Tracking Low Back Problems in a Major Self-Insured Workforce: Toward Improvement in the Patient’s Journey. Journal of Occupational and Environmental Medicine. 2014;56(6):604–620.24854253
81 Howe DH, Newcombe RG, Wade MT Manipulation of the cervical spine--a pilot study. J R Coll Gen Pract. Sep 1983;33(254):574–579.6355460
82 Nordemar R, Thorner C Treatment of acute cervical pain--a comparative group study. Pain. Feb 1981;10(1):93–101.6972028
83 Pikula JR The effect of spinal manipulative therapy (SMT) on pain reduction and range of motion in patients with acute unilateral neck pain: a pilot study. The Journal of the Canadian Chiropractic Association. 1999;43(2):111.
84 Gonzalez-Iglesias J, Fernandez-de-las-Penas C, Cleland JA, Gutierrez-Vega Mdel R Thoracic spine manipulation for the management of patients with neck pain: a randomized clinical trial. J Orthop Sports Phys Ther. Jan 2009;39(1):20–27.19209478
85 Gonzalez-Iglesias J, Fernandez-de-las-Penas C, Cleland JA, Alburquerque-Sendin F, Palomeque-del-Cerro L, Mendez-Sanchez R Inclusion of thoracic spine thrust manipulation into an electro-therapy/thermal program for the management of patients with acute mechanical neck pain: a randomized clinical trial. Man Ther. Jun 2009;14(3):306–313.18692428
86 Puentedura EJ, Cleland JA, Landers MR, Mintken P, Louw A, Fernández-de-las-Peñas C Development of a clinical prediction rule to identify patients with neck pain likely to benefit from thrust joint manipulation to the cervical spine. journal of orthopaedic & sports physical therapy. 2012;42(7):577–592.22585595
87 Dunning JR, Cleland JA, Waldrop MA, . Upper cervical and upper thoracic thrust manipulation versus nonthrust mobilization in patients with mechanical neck pain: a multicenter randomized clinical trial. journal of orthopaedic & sports physical therapy. 2012;42(1):5–18.21979312
88 Furlan AD, Pennick V, Bombardier C, van Tulder M 2009 updated method guidelines for systematic reviews in the Cochrane Back Review Group. Spine. 2009;34(18):1929–1941.19680101