# INTRODUCTION

Back pain and neck pain are among the most common symptoms prompting patients to seek care. While data specific to Veterans are not available, in the general population lifetime prevalence estimates of low back pain are as high as 80% in the US population. Most persons can expect to have an episode of acute back pain, acute neck pain, or both at some point.

Many treatments are used for back pain without having been established as so clearly superior as to extinguish the use of others. Treatments include analgesics, muscle relaxants, bed rest, exercises, physical therapy modalities, heat, ice, spinal manipulation, acupuncture, and others.

Spinal manipulative therapy (SMT) is a treatment option available in VA, provided mostly but not entirely by Doctors of Chiropractic. In practice, most patients referred to VA chiropractors have chronic pain. In order to better understand the potential role of SMT in treating acute back or neck pain, VA requested an up-to-date synthesis of the evidence.

There have been several prior reviews on spinal manipulation, including one by a member of the ESP team that concluded SMT is superior to a sham, but not clearly superior to other effective treatments for acute low back pain.^1^ The most recent Cochrane Review on the subject, however, concluded that SMT is not more effective than any other intervention or sham.^2^ Thus, one goal of this review is to help resolve disagreements in the results from prior reviews.