# APPENDIX D EVIDENCE TABLE OF 26 RANDOMIZED CLINICAL TRIALS OF SPINAL MANIPULATIVE THERAPY FOR ACUTE LOW BACK PAIN

Author, Year | Setting | % Male | Mean Age | Presence of Leg Pain or Sciatica | Outcome | Baseline value | Treatment arms | Sample Size | Follow-up
Bergquist-Ullman, et al, 1977^25^ | Industry | 87% male | 34 years | 14% of patients had a straight leg raise test positive at less than 60 degrees | Pain index | 43 | back school (instruction and exercise) | N=44 | 10 day median: 20 3 week median: 19 6 week median: 22
Bergquist-Ullman, et al, 1977^25^ | Industry | 87% male | 34 years | 14% of patients had a straight leg raise test positive at less than 60 degrees | Pain index | 42 | non-thrust manipulation | N=50 | 10 day median: 22 3 week median: 18 6 week median: 21
Bergquist-Ullman, et al, 1977^25^ | Industry | 87% male | 34 years | 14% of patients had a straight leg raise test positive at less than 60 degrees | Pain index | 42 | diathermy according to Cyriax, Kaltenborn, Lewit, and Janda | N=56 | 10 day median: 28 3 week median: 25 6 week median: 17
Blomberg, et al, 1994^17–21^ | Primary care | 52% male | 37 years | 10% with “true radicular pain” | Disability Rating Score (function) | no baseline data | usual medical care | N=48 | 3 days mean: 4.6 1 week mean: 3.9 2 week mean: 3.2 3 week mean: 3
Blomberg, et al, 1994^17–21^ | Primary care | 52% male | 37 years | 10% with “true radicular pain” | Disability Rating Score (function) | no baseline data | mix of thrust and non- thrust manipulation, some patients also got steroid injections of the parasacrococcygeal structures as described by Cyriax | N=53 | 3 days mean: 3.5 1 week mean: 2.6 2 week mean: 1.8 3 week mean: 1.4
Blomberg, et al, 1994^17–21^ | Primary care | 52% male | 37 years | 10% with “true radicular pain” | Pain score | no baseline data | usual medical care | N=48 | 3 days mean: 4.8 1 week mean: 4.2 2 week mean: 3.4 3 week mean: 3.4
Blomberg, et al, 1994^17–21^ | Primary care | 52% male | 37 years | 10% with “true radicular pain” | Pain score | no baseline data | mix of thrust and non- thrust manipulation, some patients also got steroid injections of the parasacrococcygeal structures as described by Cyriax | N=53 | 3 days mean: 3.8 1 week mean: 3.1 2 week mean: 2 3 week mean: 1.7
Cherkin, et al, 1998^3^ | Primary care patients from health maintenance organization | 52% male | 41 years | Sciatica excluded | Roland Morris Disability questionnaire (function) | 12.1 (CI: 11.2–13.1) | thrust manipulation | N=122 | 4 week mean: 3.7 (2.9 SD)
Cherkin, et al, 1998^3^ | Primary care patients from health maintenance organization | 52% male | 41 years | Sciatica excluded | Roland Morris Disability questionnaire (function) | 11.7 ( CI: 10.4–13.0) | physical therapy according to McKenzie | N=136 | 4 week mean: 4.1 (3.3 SD)
Cherkin, et al, 1998^3^ | Primary care patients from health maintenance organization | 52% male | 41 years | Sciatica excluded | Roland Morris Disability questionnaire (function) | 11.7 (CI: 10.4–13.0) | educational booklet | N=66 | 4 week mean: 4.9 (3.8 SD)
Cherkin, et al, 1998^3^ | Primary care patients from health maintenance organization | 52% male | 41 years | Sciatica excluded | Bothersomene ss of symptoms (pain) | 5.5 (CI: 5.1– 5.8) | thrust manipulation | N=122 | 4 week mean: 1.9 (1.5 SD)
Cherkin, et al, 1998^3^ | Primary care patients from health maintenance organization | 52% male | 41 years | Sciatica excluded | Bothersomene ss of symptoms (pain) | 6 (CI: 5.6– 6.5) | physical therapy according to McKenzie | N=136 | 4 week mean: 2.3 (1.9 SD)
Cherkin, et al, 1998^3^ | Primary care patients from health maintenance organization | 52% male | 41 years | Sciatica excluded | Bothersomene ss of symptoms (pain) | 5.3 (CI: 4.9– 5.7) | educational booklet | N=66 | 4 week mean: 3.1 (2.4 SD)
Childs, et al, 2004^26^ | 8 physical therapy clinics in the United States | 58% male | 34 years | 24% had “symptoms distal to knee” | Oswestry disability questionnaire (function) | 41.4 (10.1 SD) | thrust manipulation | N=70 | 1 week mean: 14.6 4 week mean: 8.4
Childs, et al, 2004^26^ | 8 physical therapy clinics in the United States | 58% male | 34 years | 24% had “symptoms distal to knee” | Oswestry disability questionnaire (function) | 40.9 (10.8 SD) | low stress aerobic exercise and lumbar spine strengthening program according to Agency for Health Care Policy and Research guidelines | N=61 | 1 week mean: 35 4 week mean: 23
Cramer, et al, 1993^27^ | Clinical chiropractic college | 57% male | Not reported | Patients with “compressive neuropathy” we excluded | Visual Analogue Scale (pain) | 71.8 (14.8 SD) | non-thrust manipulation and electrical stimulation and cold pack | N=17 | 10 day mean: 38.6 (25.2 SD)
Cramer, et al, 1993^27^ | Clinical chiropractic college | 57% male | Not reported | Patients with “compressive neuropathy” we excluded | Visual Analogue Scale (pain) | 72 (19.2 SD) | detuned ultrasound and cold pack | N=18 | 10 day mean: 42 (28.8 SD)
Cramer, et al, 1993^27^ | Clinical chiropractic college | 57% male | Not reported | Patients with “compressive neuropathy” we excluded | Oswestry disability questionnaire (function) | 17.6 (11.9 SD) | non-thrust manipulation and electrical stimulation and cold pack | N=17 | 10 day mean: 7.3 (6.8 SD)
Cramer, et al, 1993^27^ | Clinical chiropractic college | 57% male | Not reported | Patients with “compressive neuropathy” we excluded | Oswestry disability questionnaire (function) | 14.9 (5.0 SD) | detuned ultrasound and cold pack | N=18 | 10 day mean: 8.0 (7.6 SD)
Cruser, et al, 2012^28^ | United States military facility | 55% male | 27 years | Not reported | Visual Analogue Scale (pain) | 5.2 (2.1 SD) | mix of thrust and non- thrust manipulation, soft tissue stretching, myofascial release, counterstrain muscle energy, sacroiliac articulation | N=30 | 4 week mean: 2.0 (1.5 SD)
Cruser, et al, 2012^28^ | United States military facility | 55% male | 27 years | Not reported | Visual Analogue Scale (pain) | 5.5 (2.2 SD) | usual medical care | N=30 | 4 week mean: 3.7 (2.4 SD)
Cruser, et al, 2012^28^ | United States military facility | 55% male | 27 years | Not reported | Roland Morris Disability questionnaire (function) | 12.4 (5.3 SD) | mix of thrust and non- thrust manipulation, soft tissue stretching, myofascial release, counterstrain muscle energy, sacroiliac articulation | N=30 | 4 week mean: 4.4 (5.9 SD)
Cruser, et al, 2012^28^ | United States military facility | 55% male | 27 years | Not reported | Roland Morris Disability questionnaire (function) | 12.5 (6.0 SD) | usual medical care | N=30 | 4 week mean: 7.31 (6.3 SD)
Delitto, et al, 1993^29^ | Physiotherapy department | 58% male | 33 years | 21% had “leg symptoms” | Oswestry disability questionnaire (function) | 33 (5 SD) | thrust manipulation and extension exercises according to McKenzie and hand-heel rock exercise | N=14 | 3 day mean: 20 (5 SD) 5 day mean: 10 (5 SD)
Delitto, et al, 1993^29^ | Physiotherapy department | 58% male | 33 years | 21% had “leg symptoms” | Oswestry disability questionnaire (function) | 41 (5 SD) | flexion exercises according to Williams | N=10 | 3 day mean: 36 (5 SD) 5 day mean: 32 (4 SD)
Erhard, et al, 1994^30^ | Physiotherapy department | 62% male | 44 years | 8% had “leg symptoms” | Oswestry disability questionnaire (function) | 45 (12 SD) | thrust manipulation and extension exercises according to McKenzie | N=12 | 3 day mean: 20 (8 SD) 5 day mean: 8 (8 SD)
Erhard, et al, 1994^30^ | Physiotherapy department | 62% male | 44 years | 8% had “leg symptoms” | Oswestry disability questionnaire (function) | 40 (12 SD) | extension exercises according to McKenzie | N=12 | 3 day mean: 35 (8 SD)5 day mean: 25 (14 SD)
Farrell, et al, 1982^31^ | Setting unclear | 62% male | 42 years | Not reported | Subjective pain rating | 4.95 | non-thrust manipulation according to Stoddart and Maitland | N=24 | 3 week mean: 0.3
Farrell, et al, 1982^31^ | Setting unclear | 62% male | 42 years | Not reported | Subjective pain rating | 5.3 | physical therapy and diathermy, isometric abdominal exercises and ergonomic instructions | N=24 | 3 week mean: 0.3
Fritz, et al, 2015^32^ | Primary care | 48% male | 37 years | Patients with presence of pain or numbness distal to the knee were excluded | Numeric pain rating of low back pain severity | no baseline data | thrust manipulation and exercises | N=108 | 4 week mean: 1.7 (1.9 SD)
Fritz, et al, 2015^32^ | Primary care | 48% male | 37 years | Patients with presence of pain or numbness distal to the knee were excluded | Numeric pain rating of low back pain severity | no baseline data | standard medical care and self-help booklet | N=112 | 4 week mean: 2.1 (1.9 SD)
Fritz, et al, 2015^32^ | Primary care | 48% male | 37 years | Patients with presence of pain or numbness distal to the knee were excluded | Oswestry disability questionnaire (function) | no baseline data | thrust manipulation and exercises | N=108 | 4 week mean: 11.1 (12.5 SD)
Fritz, et al, 2015^32^ | Primary care | 48% male | 37 years | Patients with presence of pain or numbness distal to the knee were excluded | Oswestry disability questionnaire (function) | no baseline data | standard medical care and self-help booklet | N=112 | 4 week mean: 14.5 (13.2 SD)
Glover, et al, 1974^33^ | Work medical center | 89% male | 39 years | Not reported | Percent pain relief | no baseline data | diathermy | N=41 | 3 day mean: 56 1 week mean: 80
Glover, et al, 1974^33^ | Work medical center | 89% male | 39 years | Not reported | Percent pain relief | no baseline data | non-thrust manipulation | N=43 | 3 day mean: 50 1 week mean: 75
Godfrey, et al, 1984^12^ | Patients referred from primary care | Not reported | 42 years | Not reported | General symptomatology (number of patients with marked improvement) (pain) | no baseline data | thrust manipulation according to Maigne | | 2–3 week: 14/39 (35.9%)
Godfrey, et al, 1984^12^ | Patients referred from primary care | Not reported | 42 years | Not reported | General symptomatology (number of patients with marked improvement) (pain) | no baseline data | light effleurage and minimal electrostimulation | | 2–3 week: 7/33 (21.2%)
Godfrey, et al, 1984^12^ | Patients referred from primary care | Not reported | 42 years | Not reported | Activities of Daily Living (number of patients with moderate improvement) (function) | no baseline data | thrust manipulation according to Maigne | | 2–3 week: 7/24 (29.2%)
Godfrey, et al, 1984^12^ | Patients referred from primary care | Not reported | 42 years | Not reported | Activities of Daily Living (number of patients with moderate improvement) (function) | no baseline data | light effleurage and minimal electrostimulation | | 2–3 week: 5/17 (29.4%)
Goertz, et al, 2013^34^ | United States army medical center | 86% male | 26 years | 43% had “radicular signs” | Numerical pain rating scale | 5.8 (2.1 SD) | standard medical care and brief massage, ice or heat, McKenzie exercises, stretching exercises | N=46 | 2 week mean: 6.1 4 week mean: 5.2
Goertz, et al, 2013^34^ | United States army medical center | 86% male | 26 years | 43% had “radicular signs” | Numerical pain rating scale | 5.8 (1.5 SD) | thrust manipulation | N=45 | 2 week mean: 3.9 4 week mean: 3.9
Goertz, et al, 2013^34^ | United States army medical center | 86% male | 26 years | 43% had “radicular signs” | Roland Morris Disability questionnaire (function) | 12.7 (5.1 SD) | standard medical care and brief massage, ice or heat, McKenzie exercises, strengthening exercises | N=46 | 2 week mean: 12.9 4 week mean: 12
Goertz, et al, 2013^34^ | United States army medical center | 86% male | 26 years | 43% had “radicular signs” | Roland Morris Disability questionnaire (function) | 11 (4.2 SD) | thrust manipulation | N=45 | 2 week mean: 8.9 4 week mean: 8
Grunnesjö, et al, 2004^22–24^ | Nine primary health care and one outpatient orthopedic hospital department | 56% male | 41 years | 8% had “verified herniations” | Pain last 24 hours | 52.2 (CI: 46.7–57.8) | stay active | N=71 | 5 week mean: 29.7 (25.8 SD)
Grunnesjö, et al, 2004^22–24^ | Nine primary health care and one outpatient orthopedic hospital department | 56% male | 41 years | 8% had “verified herniations” | Pain last 24 hours | 54.7 (CI: 49.8–59.6) | mix of thrust and non- thrust manipulation and stay active and in some patients a steroid injection in the parasacrococcygeal region | N=89 | 5 week mean: 20.8 (23.3 SD)
Grunnesjö, et al, 2004^22–24^ | Nine primary health care and one outpatient orthopedic hospital department | 56% male | 41 years | 8% had “verified herniations” | All disability rating variables | 52 (CI: 47.4–56.6) | stay active | N=71 | 5 week mean: 31.9 (21.9 SD)
Grunnesjö, et al, 2004^22–24^ | Nine primary health care and one outpatient orthopedic hospital department | 56% male | 41 years | 8% had “verified herniations” | All disability rating variables | 57.8 (CI: 53.7–61.8) | mix of thrust and non- thrust manipulation and stay active and in some patients a steroid injection in the parasacrococcygeal region | N=89 | 5 week mean: 25.8 (22.1 SD)
Hadler, et al, 1987^35^ | Primary care | 57% male | Not reported | Not reported | Roland Morris Disability questionnaire (function) | no baseline data | mobilization | N=28 | 9 day mean: 4.5 12 day mean: 3.7
Hadler, et al, 1987^35^ | Primary care | 57% male | Not reported | Not reported | Roland Morris Disability questionnaire (function) | no baseline data | thrust manipulation | N=26 | 9 day mean: 3.7 12 day mean: 3.4
Hallegraeff, et al, 2009^13^ | Three physical therapy and manual therapy centers | 55% male | 39 years | Patients with symptoms distal to the knee were excluded | Oswestry disability questionnaire (function) | 0.24 (0.18 SD) | thrust manipulation | N=31 | 2.5 week mean: 0.14 (0.17 SD)
Hallegraeff, et al, 2009^13^ | Three physical therapy and manual therapy centers | 55% male | 39 years | Patients with symptoms distal to the knee were excluded | Oswestry disability questionnaire (function) | 0.26 (0.12 SD) | physical therapy | N=33 | 2.5 week mean: 0.14 (0.12 SD)
Hallegraeff, et al, 2009^13^ | Three physical therapy and manual therapy centers | 55% male | 39 years | Patients with symptoms distal to the knee were excluded | Visual Analogue Scale (pain) | 42.7 (18.4 SD) | thrust manipulation | N=31 | 2.5 week mean: 19 (16.9 SD)
Hallegraeff, et al, 2009^13^ | Three physical therapy and manual therapy centers | 55% male | 39 years | Patients with symptoms distal to the knee were excluded | Visual Analogue Scale (pain) | 54 (17.5 SD) | physical therapy | N=33 | 2.5 week mean: 24.8 (20.1 SD)
Hancock, et al, 2007^4^ | Patients referred from primary care | 56% male | 41 years | Patients with “nerve root compromise” were excluded | Numerical pain rating scale negative effect size favors manipulation | no baseline data | non-thrust manipulation | N=59 | 1 week effect size: 0.2 (CI: −0.3–0.7) 2 week effect size: − 0.4 (CI: −1.0, 0.1) 4 week effect size: − 0.2 (CI: −0.7, 0.3)
Hancock, et al, 2007^4^ | Patients referred from primary care | 56% male | 41 years | Patients with “nerve root compromise” were excluded | Numerical pain rating scale negative effect size favors manipulation | no baseline data | detuned pulsed ultrasound (sham) | N=60
Hancock, et al, 2007^4^ | Patients referred from primary care | 56% male | 41 years | Patients with “nerve root compromise” were excluded | Roland Morris Disability questionnaire (function) negative effect size favors manipulation | no baseline data | non-thrust manipulation | N=59 | 1 week effect size: − 0.7 (CI: −2.1, 0.6) 2 week effect size: − 1.4 (CI: −2.7, −0.1) 4 week effect size: −1 (CI: −2.1, 0.1)
Hancock, et al, 2007^4^ | Patients referred from primary care | 56% male | 41 years | Patients with “nerve root compromise” were excluded | Roland Morris Disability questionnaire (function) negative effect size favors manipulation | no baseline data | detuned pulsed ultrasound (sham) | N=60
Heymann, et al, 2013^36^ | 5 orthopedic or general practices | 60% male | 37 years | Not reported | Roland Morris Disability questionnaire (function) | 13.5 (5.6 SD) | thrust manipulation | N=38 | 1 week mean: 5.8
Heymann, et al, 2013^36^ | 5 orthopedic or general practices | 60% male | 37 years | Not reported | Roland Morris Disability questionnaire (function) | 14.4 (4.8 SD) | analgesic (diclofenac) | N=37 | 1 week mean: 9.7
Heymann, et al, 2013^36^ | 5 orthopedic or general practices | 60% male | 37 years | Not reported | Roland Morris Disability questionnaire (function) | 15 (3.8 SD) | sham | N=25 | no data provided
Heymann, et al, 2013^36^ | 5 orthopedic or general practices | 60% male | 37 years | Not reported | Visual Analogue Scale (pain) | no baseline data | thrust manipulation | N=38 | 1 week mean: 10
Heymann, et al, 2013^36^ | 5 orthopedic or general practices | 60% male | 37 years | Not reported | Visual Analogue Scale (pain) | no baseline data | analgesic | N=37 | 1 week mean: 30
Heymann, et al, 2013^36^ | 5 orthopedic or general practices | 60% male | 37 years | Not reported | Visual Analogue Scale (pain) | no baseline data | sham | N=25 | 1 week mean: no data provided
Hoiriis, et al, 2004^37^ | Patients recruited via advertisement | 57% male | 42 years | Patients with “known or suspected disk herniation” were excluded | Visual Analogue Scale (pain) | 4.52 (1.82 SD) | thrust manipulation | N=34 | 2 week mean: 2.4 (2.2 SD) 4 week mean: 1.7 (1.9 SD)
Hoiriis, et al, 2004^37^ | Patients recruited via advertisement | 57% male | 42 years | Patients with “known or suspected disk herniation” were excluded | Visual Analogue Scale (pain) | 3.9 (2.0 SD) | muscle relaxants (cyclobenzaprine or carisoprodol or methocarbamol) | N=36 | 2 week mean: 2.7 (2.2 SD) 4 week mean: 2.2 (2.2 SD)
Hoiriis, et al, 2004^37^ | Patients recruited via advertisement | 57% male | 42 years | Patients with “known or suspected disk herniation” were excluded | Visual Analogue Scale (pain) | 3.8 (1.6 SD) | sham | N=40 | 2 week mean: 3.2 (2.4 SD) 4 week mean: 2.2 (2.0 SD)
Hoiriis, et al, 2004^37^ | Patients recruited via advertisement | 57% male | 42 years | Patients with “known or suspected disk herniation” were excluded | Oswestry disability questionnaire (function) | 24.8 (11.5 SD) | thrust manipulation | N=46 | 2 week mean: 17.0 (13.8 SD) 4 week mean: 11.9 (11.9 SD)
Hoiriis, et al, 2004^37^ | Patients recruited via advertisement | 57% male | 42 years | Patients with “known or suspected disk herniation” were excluded | Oswestry disability questionnaire (function) | 22.8 (12.9 SD) | muscle relaxants (cyclobenzaprine or carisoprodol or methocarbamol) | N=47 | 2 week mean: 17.0 (12.2 SD) 4 week mean:16.0 (16.1 SD)
Hoiriis, et al, 2004^37^ | Patients recruited via advertisement | 57% male | 42 years | Patients with “known or suspected disk herniation” were excluded | Oswestry disability questionnaire (function) | 24.8 (11.7 SD) | sham | N=48 | 2 week mean: 19.3 (13.7 SD) 4 week mean: 16.3 (12.6 SD)
Juni, et al, 2009^38^ | Patients referred from emergency department or a general practice | 64% male | 35 years | Patients with “signs of nerve root irritation or compression” were excluded | Roland Morris Disability questionnaire (function) | 12.8 (5.1 SD) | Mix of thrust and non-thrust manipulation | N=52 12.8 (5.1 SD) | 2 week mean: 5.8 (5.7 SD)
Juni, et al, 2009^38^ | Patients referred from emergency department or a general practice | 64% male | 35 years | Patients with “signs of nerve root irritation or compression” were excluded | Roland Morris Disability questionnaire (function) | 14.3 (4.9 SD) | analgesic (paracetamol, diclofenac, or dihydrocodeine) | N=52 | 2 week mean: 5.2 (7.0 SD)
Juni, et al, 2009^38^ | Patients referred from emergency department or a general practice | 64% male | 35 years | Patients with “signs of nerve root irritation or compression” were excluded | Pain intensity, BS-11 score positive favors manipulation | 6.3 (2.2 SD) | mix of thrust and non-thrust manipulation | N=52 | Difference of 0.5 (2.6 SD)
Juni, et al, 2009^38^ | Patients referred from emergency department or a general practice | 64% male | 35 years | Patients with “signs of nerve root irritation or compression” were excluded | Pain intensity, BS-11 score positive favors manipulation | 6.8 (2.2 SD) | Analgesic (paracetamol, diclofenac, or dihydrocodeine) | N=52
MacDonald, et al, 1990^39^ | General practice | 41% male | Not reported | Patients with “neurologic deficits” were excluded | Improvement in the disability index | 6.4 (3 SD) | thrust manipulation and advice on posture, exercises and avoidance of occupational stress | N=36 | 2 week mean: 4.1 (3.5 SD)
MacDonald, et al, 1990^39^ | General practice | 41% male | Not reported | Patients with “neurologic deficits” were excluded | Improvement in the disability index | 6.1 (2.5 SD) | advice on posture, exercise, and avoidance of occupational stress | N=30 | 2 week mean: 4.4 (3.5 SD)
Morton, 1999^40^ | Patients referred from primary care | 34% male | 44 years | Patients with “abnormalities on neurologic exam” were excluded | Roland Morris Disability questionnaire (function) | 10.6 (5.2 SD) | thrust manipulation | N=15 | 1 week mean: 6.9 (4.1 SD) 2 week mean: 6.0 (2.3 SD) 3 week mean: 3.7 (3.7 SD) 4 week mean: 1.9 (2.5 SD)
Morton, 1999^40^ | Patients referred from primary care | 34% male | 44 years | Patients with “abnormalities on neurologic exam” were excluded | Roland Morris Disability questionnaire (function) | 10.1 (6.4 SD) | spinal stabilizing exercises | N=14 | 1 week mean: 9.1 (5.9 SD) 2 week mean: 7.9 (6.3 SD) 3 week mean: 7 (6.1 SD) 4 week mean: 6 (5.2 SD)
Morton, 1999^40^ | Patients referred from primary care | 34% male | 44 years | Patients with “abnormalities on neurologic exam” were excluded | Visual Analogue Scale (pain) | 49.7 (23.6 SD) | thrust manipulation | N=15 | 1 week mean: 27.6 (15.2 SD) 2 week mean: 17.4 (13.9 SD) 3 week mean: 7.5 (6.4 SD) 4 week mean: 2.4 (3 SD)
Morton, 1999^40^ | Patients referred from primary care | 34% male | 44 years | Patients with “abnormalities on neurologic exam” were excluded | Visual Analogue Scale (pain) | 46.6 (25.1 SD) | spinal stabilizing exercises | N=14 | 1 week mean: 46.4 (23.3 SD) 2 week mean: 36.6 (24.6 SD) 3 week mean: 34.5 (23 SD) 4 week mean: 25.4 (17.3 SD)
Postacchini, et al, 1988^41^ | Hospital outpatient department | 51% male | 38 years | Not reported | Improvement in low back pain from pre- treatment | no baseline data | thrust manipulation | N=53 | 3 week mean: 8.5
Postacchini, et al, 1988^41^ | Hospital outpatient department | 51% male | 38 years | Not reported | Improvement in low back pain from pre- treatment | no baseline data | back school | N=17 | 3 week mean: 10.4
Postacchini, et al, 1988^41^ | Hospital outpatient department | 51% male | 38 years | Not reported | Improvement in low back pain from pre- treatment | no baseline data | analgesics (diclofenac) | N=49 | 3 week mean: 9.4
Postacchini, et al, 1988^41^ | Hospital outpatient department | 51% male | 38 years | Not reported | Improvement in low back pain from pre- treatment | no baseline data | physiotherapy of light massage, analgesic currents, and diathermy | N=47 | 3 week mean: 8.1
Postacchini, et al, 1988^41^ | Hospital outpatient department | 51% male | 38 years | Not reported | Improvement in low back pain from pre- treatment | no baseline data | bed rest | N=29 | 3 week mean: 6.6
Postacchini, et al, 1988^41^ | Hospital outpatient department | 51% male | 38 years | Not reported | Improvement in low back pain from pre- treatment | no baseline data | topical gel | N=46 | 3 week mean: 5.8
Rasmussen, 1979^42^ | Hospital department of physical medicine and rheumatology | Not reported | 35 years | Patients with “signs of root pressure” were excluded | Number of patients with total restorement of all symptoms | no baseline data no baseline data | non-thrust manipulation | N=12 | 11/12 (91.7%)
Rasmussen, 1979^42^ | Hospital department of physical medicine and rheumatology | Not reported | 35 years | Patients with “signs of root pressure” were excluded | Number of patients with total restorement of all symptoms | no baseline data no baseline data | diathermy | N=12 | 3/12 (25%)
Skargren, et al, 1998^43^ | Primary care centers | 38% male | 41 years | Not reported | Visual Analogue Scale (pain) negative favors manipulation | 56 (22 SD) | thrust manipulation | N=172 | 4–5 week difference: − 0.16 (CI: −6.47, 6.15)
Skargren, et al, 1998^43^ | Primary care centers | 38% male | 41 years | Not reported | Visual Analogue Scale (pain) negative favors manipulation | 61 (21 SD) | physiotherapy | N=144
Skargren, et al, 1998^43^ | Primary care centers | 38% male | 41 years | Not reported | Oswestry disability questionnaire (function) negative favors manipulation | 35 (17 SD) | thrust manipulation | N=172 | 4–5 week difference: − 1.49 (CI: −5.51, 2.54)
Skargren, et al, 1998^43^ | Primary care centers | 38% male | 41 years | Not reported | Oswestry disability questionnaire (function) negative favors manipulation | 37 (16 SD) | physiotherapy | N=144
Waterworth, et al, 1985^44^ | General practice | 62% male | 36 years | Not reported | Score of lower back pain | 2.1 | non-thrust manipulation | N=38 | 12 day mean: 0.42
Waterworth, et al, 1985^44^ | General practice | 62% male | 36 years | Not reported | Score of lower back pain | 2.1 | analgesic (diflunisal) | N=36 | 12 day mean: 0.44
Waterworth, et al, 1985^44^ | General practice | 62% male | 36 years | Not reported | Score of lower back pain | 2 | physiotherapy including local heat, ultrasound, and flexion and extension exercises | N=34 | 12 day mean: 0.38
Waterworth, et al, 1985^44^ | General practice | 62% male | 36 years | Not reported | Patient has overall improvement score of excellent | no baseline data | non-thrust manipulation | N=38 | 23/38 (60.5%)
Waterworth, et al, 1985^44^ | General practice | 62% male | 36 years | Not reported | Patient has overall improvement score of excellent | no baseline data | analgesic (diflunisal) | N=36 | 15/36 (41.7%)
Waterworth, et al, 1985^44^ | General practice | 62% male | 36 years | Not reported | Patient has overall improvement score of excellent | no baseline data | physiotherapy including local heat, ultrasound, and flexion and extension exercises | N=34 | 13/34 (38.2%)