# APPENDIX C PEER REVIEW COMMENTS/AUTHOR RESPONSES

Comment | Response
Recommend considering change to the time labels given to the outcome periods. Currently these labels are “short term” and “long term.” Traditionally “long term” outcomes for low back pain would be considered to be 3–12 months rather than 3–6 weeks. To the casual reader, this may be misleading. | We have updated these time labels so that less than 2 weeks is now “immediate” instead of “short” and 3 to 6 weeks is “short” instead of “long” term. These labels were chosen to align with terms used by a previous publication: Chou et al. Epidural corticosteroid injections for radiculopathy and spinal stenosis. Ann Intern Med. 2015; 163 (5): 373–381.
I recommend considering addition of a measure of clinical importance to the outcomes. For example, use of the Minimum Clinically Important Difference (MCID) may help the reader to interpret the clinical significance of relatively small changes in pain and function. | We have now incorporated a discussion of MCID into the Data Synthesis section. Choosing an MCID for the Roland Scale proved challenging, and in the report we explain this in detail.
Also consider including a reference or explanation of what is statistically and clinically significant change in pain and function for the reader | We have now incorporated a discussion of MCID into the Data Synthesis section. Choosing an MCID for the Roland Scale proved challenging, and in the report we explain this in detail.
Consider including a reference for readers to refer to and learn about forest plots. Some readers may not be familiar with this idea. The extensive use of forest plots would support educating readers on this subject. | We have now incorporated a reference at our first mention of forest plots in the Data Synthesis section: Greenhalgh T. How to read a paper: Papers that summarise other papers (systematic reviews and meta-analyses). BMJ. 1997;315(7109):672–675.
Page 3, first paragraph - the sentence is confusing. “six studies each scored 3 points and 2 points.” Maybe change to “six studies scored 3 points and the other 6 studies scored 2 points”. | This change has been made.
Page 8, line 22 “ESP” is not defined. Consider including what this acronym is. | This change has been made.
Page 9, line 9 – Participants are defined as “Adults”. Consider defining what an adult is such as 18+ and children as less than 18 years of age. | This change has been made.
Page 9, line 16 – Spinal manipulation is not clearly defined. Consider adding the HVLA definition here or referring the reader to the second paragraph under data extraction on page 9. | We have added language that refers readers to the mentioned data abstraction section.
Page 9, line 30 – settings: Why were hospital settings excluded? The VA is a hospital-based setting. I suggest including the rationale for excluding these studies. | The decision to focus only on ambulatory patients was made at the outset by the topic nominators; this was specified in the Topic Nomination Brief.
Page 9, line 55 – was TEP defined earlier? If not define this acronym. | This change has been made
Page 26, line 15 the word enrollment is misspelled. | This change has been made.
Published or unpublished studies that may have been overlooked:; 1. Puentedura CPR for cervical manipulation versus non-thrust (validation pending),; 2. Dunning CPR for cervical AND thoracic thrust versus cervical and thoracic non-thrust.; 3. Cook 2012 Manual Therapy article also directly compares thrust to non-thrust manipulation for LBP. | (1 & 2) These articles did not meet inclusion criteria because the pain was not acute in their patient populations, and are now in the “exclude-background” group for their relevance to clinical prediction rules. They have been incorporated into the text. (3) This article was identified by our searches but excluded from our review because it did not focus on acute pain.
Other ESPs have included cohort studies in the analysis, particularly in the area of assessing harms. I realize that you have included some prospective cohort studies in the harms analysis. However I would suggest including some of the higher quality retrospective cohort studies that have looked at harms and opiate use. Understood that this would be lower level evidence, however even a sidebar discussion of this can help provide some better information, particularly in light of the current situation regarding opiate use for musculoskeletal pain. | We have now incorporated the 7 articles identified by the reviewer into either the Serious Adverse Events section (Cassidy, Kosloff, Whedon) or the Key Question 2 section (Rhee, Vogt, Franklin, Allen) with discussion where appropriate.
I understood (perhaps incorrectly) at the outset that this ESP would also include review/analysis of retrospective cohort studies of harms and opiate use? If this was accomplished, I may have overlooked this information given there are only a few - but important - such reports. Our office considers this information relevant and important, particularly given the increased scrutiny on use of opiates for pain management, and rehabilitative alternatives (such as chiropractic, CAM, and other various treatment modalities).