# APPENDIX B COCHRANE BACK GROUP RISK OF BIAS TOOL

## COCHRANE BACK REVIEW GROUP (CBRG) CRITERIA

2003 Version^88^

Domain | Operationalization of the Criteria List | Reviewers’ judgment
V1. Randomization | A random (unpredictable) assignment sequence. Examples of adequate methods are computer generated random number table and use of sealed opaque envelopes. Methods of allocation using date of birth, date of admission, hospital numbers, or alternation should not be regarded as appropriate. | Was the method of randomization adequate? Yes/No/Don’t Know
V2. Concealment | Assignment generated by an independent person not responsible for determining the eligibility of the patients. This person has no information about the persons included in the trial and has no influence on the assignment sequence or on the decision about eligibility of the patient. | Was the treatment allocation concealed? Yes/No/Don’t Know
V3. Baseline differences | In order to receive a yes, groups have to be similar at baseline regarding demographic factors, duration and severity of complaints, percentage of patients with neurologic symptoms, and value of main outcome measure(s). [adapt as required by topic] | Were the groups similar at baseline regarding the most important prognostic indicators? Yes/No/Don’t Know
V4. Blinding - patient | The reviewer determines if enough information about blinding is given in order to score a yes. | Was the patient blinded to the intervention? Yes/No/Don’t Know
V5. Blinding – care provider | The reviewer determines if enough information about blinding is given in order to score a yes. | Was the care provider blinded to the intervention? Yes/No/Don’t Know
V6. Blinding - outcome | The reviewer determines if enough information about blinding is given in order to score a yes. | Was the outcome assessor blinded to the intervention? Yes/No/Don’t Know
V7. Co- interventions | Co-interventions should either be avoided in the trial design or similar between the index and control groups. | Were co-interventions avoided or similar? Yes/No/Don’t Know
V8. Compliance | The reviewer determines if the compliance to the interventions is acceptable, based on the reported intensity, duration, number and frequency of sessions for both the index intervention and control intervention(s). | Was the compliance acceptable in all groups? Yes/No/Don’t Know
V9. Dropouts | The number of participants who were included in the study but did not complete the observation period or were not included in the analysis must be described and reasons given. If the percentage of withdrawals and drop-outs does not exceed 20% for short-term follow-up and 30% for long-term follow-up and does not lead to substantial bias a yes is scored. (N.B. these percentages are arbitrary, not supported by literature) | Was the drop-out rate described and acceptable? Yes/No/Don’t Know
V10. Timing | Timing of outcome assessment should be identical for all intervention groups and for all important outcome assessments. | Was the timing of the outcome assessment in all groups similar? Yes/No/Don’t Know
V11. ITT | All randomized patients are reported/analyzed in the group they were allocated to by randomization for the most important moments of effect measurement (minus missing values) irrespective of noncompliance and co-interventions. | Did the analysis include an intention-to-treat analysis? Yes/No/Don’t Know