# APPENDIX A SEARCH STRATEGIES

## 1 SYSTEMATIC REVIEW SEARCH STRATEGIES

### SEARCH STRATEGY FOR “CHIROPRACTIC” SYSTEMATIC REVIEWS

#### DATABASE SEARCHED

Cochrane Database of Systematic Reviews and Other Reviews

NO DATE OR LANGUAGE LIMITATIONS

#### SEARCH STRATEGY

‘chiroprac* in Title, Abstract, Keywords

Cochrane Reviews (17)

Other Reviews (44)

#### SEARCH STRATEGY

“Manipulation, Spinal”
Cochrane Database Search Strategy #2: spine or spinal or neck or back or cervi* and (smt or manipulat* or chiropract*):ti,ab,kw
Dates: 2011-present,
Limit to the Cochrane Systematic Reviews, Other Reviews (DARE), Technology Assessments, and Economic Evaluations databases.

Forward search on:

Hurwitz EL, Aker PD, Adams AH, Meeker WC, Shekelle PG. Manipulation and mobilization of the cervical spine. A systematic review of the literature. Spine (Phila Pa 1976). Aug 1 1996;21(15):1746–1759; discussion 1759–1760.8855459

## 2 UPDATE SEARCH STRATEGIES

### SPINAL MANIPULATION THERAPY – 2015 UPDATE SEARCH METHODOLOGY

#### DATABASE SEARCHED & TIME PERIOD COVERED

COCHRANE CENTRAL – 1/1/2011–2/06/2017

#### SEARCH STRATEGY

#1 MeSH descriptor: [Back] explode all trees
#2 MeSH descriptor: [Buttocks] this term only
#3 MeSH descriptor: [Leg] this term only
#4 MeSH descriptor: [Back Pain] explode all trees
#5 MeSH descriptor: [Back Pain] 1 tree(s) exploded
#6 MeSH descriptor: [Back Injuries] explode all trees
#7 MeSH descriptor: [Low Back Pain] this term only
#8 MeSH descriptor: [Sciatica] this term only
#9 low next back next pain
#10 lbp
#11 #1 or #2 or #3 or #5 or #6 or #7 or #8 or #9 or #10
#12 MeSH descriptor: [Musculoskeletal Manipulations] explode all trees
#13 MeSH descriptor: [Chiropractic] explode all trees
#14 manip*
#15 MeSH descriptor: [Osteopathic Medicine] explode all trees
#16 osteopath*
#17 chiropract*
#18 #12 or #13 or #14 or #15 or #16 or #17
#19 #11 and #18

#### DATABASE SEARCHED & TIME PERIOD COVERED

MEDLINE ON OVID – 1/1/2011–2/06/2017

#### SEARCH STRATEGY

1. Clinical Trial.pt.
2. randomized.ab,ti.
3. placebo.ab,ti.
4. dt.fs.
5. randomly.ab,ti.
6. trial.ab,ti.
7. groups.ab,ti.
8. 1 or 2 or 3 or 4 or 5 or 6 or 7
9. Animals/
10. Humans/
11. 9 not (9 and 10) Including Related Terms
12. 8 not 11
13. dorsalgia.ti,ab.
14. exp Back Pain/
15. backache.ti,ab.
16. (lumbar adj pain).ti,ab.
17. coccyx.ti,ab.
18. coccydynia.ti,ab.
19. sciatica.ti,ab.
20. sciatica/
21. spondylosis.ti,ab.
22. lumbago.ti,ab.
23. exp low back pain/
24. 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23
25. exp Manipulation, Chiropractic/
26. exp Manipulation, Orthopedic/
27. exp Manipulation, Osteopathic/
28. exp Manipulation, Spinal/
29. exp Musculoskeletal Manipulations/
30. exp Chiropractic/
31. manipulation.mp.
32. manipulate.mp.
33. exp Orthopedics/
34. exp Osteopathic Medicine/
35. 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34
36. 12 and 24 and 35
37. 36 and 2011:2015.(sa_year).

#### DATABASE SEARCHED & TIME PERIOD COVERED

EMBASE – 1/1/2011–2/06/2017

#### SEARCH STRATEGY

#2 ‘clinical article’/exp OR ‘clinical study’/exp OR ‘clinical trial’/de OR ‘controlled study’/de OR ‘randomized controlled trial’/de OR ‘major clinical study’/de OR ‘double blind procedure’/de OR ‘multicenter study’/de OR ‘single blind procedure’/de OR ‘phase 3 clinical trial’/de OR ‘phase 4 clinical trial’/de OR ‘crossover procedure’/de OR ‘placebo’/de
#6 allocat*
#7 assign*
#8 blind*
#12 clinical NEAR/25 (study OR trial*)
#13 compar*
#14 control*
#17 ‘cross over’
#18 ‘cross-over’
#19 ‘crossover’
#20 factorial
#21 ‘follow up’
#22 follow* NEAR/3 up
#23 ‘follow up’
#24 placebo*
#25 prospectiv*
#26 random*
#27 (singl* OR doubl* OR trebl* OR tripl*) NEAR/25 (blind* OR mask*)
#28 trial
#29 versus OR vs
#30 #6 OR #7 OR #8 OR #12 OR #13 OR #14 OR #17 OR #18 OR #19 OR #20 OR #21 OR #22 OR #23 OR #24 OR #25 OR #26 OR #27 OR #28 OR #29
#31 #2 OR #30
#34 dorsalgia
#35 ‘back pain’
#36 lumbar NEAR/2 pain
#37 coccyx
#38 coccydynia
#39 sciatica
#40 spondylosis
#41 lumbago
#42 ‘backache’/exp OR ‘ischialgia’/exp OR ‘low back pain’/exp
#43 #34 OR #35 OR #36 OR #37 OR #38 OR #39 OR #40 OR #41 OR #42
#44 ‘chiropractic’/exp OR ‘orthopedic manipulation’/exp OR ‘manipulative medicine’/exp OR ‘osteopathic medicine’/exp OR ‘orthopedics’/exp
#45 manipulation
#46 manipulate
#47 osteopathy
#48 #44 OR #45 OR #46 OR #47
#49 #31 AND #43 AND #48
#50 #31 AND #43 AND #48 AND [humans]/lim
#51 #31 AND #43 AND #48 AND [humans]/lim AND [2011–2015]/py

#### DATABASE SEARCHED & TIME PERIOD COVERED

CINAHL – 1/1/2011–2/06/2017

#### SEARCH STRATEGY

Search modes - Find all search terms (For all search statements)

S1 randomized controlled trials
S2 randomized controlled trials
S3 PT clinical trial
S4 (MH “Clinical Trials+”)
S5 clin* n25 trial*
S6 (singl* or doubl* or trebl* or tripl*) n25 (blind* or mask*)
S7 (MH “Placebos”)
S8 (MH “Study Design+”)
S9 (MH “Comparative Studies”)
S10 (MH “Evaluation Research+”)
S11 (MH “Prospective Studies+”)
S12 “follow up studies” OR “follow-up studies” OR “followup studies” OR “follow-up study” OR “follow up study” OR “followup study”
S13 control* or prospectiv* or volunteer*
S14 placebo* OR random* OR (latin n2 square*)
S15 S2 OR S3 OR S4 OR S5 OR S6 OR S7 OR S8 OR S9 OR S10 OR S11 OR S12 OR S13 OR S14
S18 TI dorsalgia OR AB dorsalgia
S19 (MH “Back Pain+”)
S20 TI backache OR AB backache
S21 TI lumbar n2 pain OR AB lumbar n2 pain
S22 TI coccyx pain OR AB lumbar n2 pain
S23 TI coccyx OR AB coccyx
S24 TI coccydynia OR AB coccydynia
S25 TI sciatica OR AB sciatica
S26 (MH “Sciatica”)
S27 TI spondylosis OR AB spondylosis
S28 TI lumbago cronico OR AB spondylosis
S29 TI lumbago OR AB lumbago
S30 (MH “Low Back Pain”)
S31 S18 OR S19 OR S20 OR S21 OR S22 OR S23 OR S24 OR S25 OR S26 OR S27 OR S28 OR S29 OR S30
S32 (MH “Chiropractic+”)
S33 (MH “Manipulation, Chiropractic”)
S34 (MH “Manipulation, Orthopedic”)
S35 (MH “Manipulation, Osteopathic”)
S36 (MH “Manual Therapy+”)
S37 (MH “Orthopedics”)
S38 (MH “Osteopathy+”)
S39 manipulation
S40 manipulate
S41 S32 OR S33 OR S34 OR S35 OR S36 OR S37 OR S38 OR S39 OR S40
S42 S15 AND S31 AND S41
S43 S15 AND S31 AND S41

#### DATABASE SEARCHED & TIME PERIOD COVERED

PubMed – 1/1/2015–2/06/2017

#### SEARCH STRATEGY

Manipulation, Chiropractic[mh] OR Manipulation, Orthopedic[mh] OR Manipulation, Osteopathic[mh] OR Manipulation, Spinal[mh] OR Musculoskeletal Manipulations[mh] OR Chiropractic[mh] OR Orthopedics OR Osteopathic Medicine

AND

“Low Back Pain”[Mesh] OR low back pain*[tiab] OR “Back”[Mesh] OR dorsalgia[tiab] OR Back Pain[mh] OR backache[tiab] OR “lumbar pain”[tiab] OR coccyx[tiab] OR coccydynia[tiab] OR sciatica[tiab] OR sciatica[mh] OR spondylosis[tiab] OR lumbago[tiab]

AND

Randomized Controlled Trial” [Publication Type] OR “Randomized Controlled Trials as Topic”[Mesh] OR random*[tiab] OR rct* OR systematic[tiab] OR systematic[sb] OR Clinical Trial[pt] OR randomized[tiab] OR placebo[tiab] OR randomly[tiab] OR trial[tiab] OR groups[tiab]