# SUMMARY AND DISCUSSION

In this review we assessed the evidence published in the United States since 1995 of family-involved interventions for improving outcomes in adult patients with cancer and memory-related conditions. We posed two key questions, first asking if these interventions are more effective at improving outcomes than usual care/wait list and second, if they are more effective at improving outcomes than other types of interventions, including health education, patient-only interventions and alternative family interventions.

Our search yielded 59 articles, representing 56 trials. Among these, 27 trials included family interventions aimed at improving outcomes for cancer patients and 29 for patients with memory-related disorders. Trials were heterogeneous and varied in the populations targeted, study size, methods of delivering interventions, and outcomes assessed. In most cases, the family intervention followed a protocol, withdrawals from the trials were adequately described (although often not by intervention condition), and exclusion/inclusion criteria for participation were clearly described. However, few studies included a description of allocation concealment or blinding procedures and measures used to assess the same construct were highly variable across trials. Treatment integrity was frequently not described, and for many studies, multiple comparisons were made, samples were small, and analyses underpowered. Veteran status of patients or family members was not explicit in most studies. While post-treatment outcomes were frequently reported, some trials did not report post-intervention data.

The purposes of family involvement also varied. In most cancer studies, the intention of the trial was to integrate families to improve patient outcomes, including relationship adjustment. However, for memory-related trials, the intention of some interventions was to reduce the burden of care for family members by helping them manage patient functioning and care. Therefore, the primary target of the intervention was family member outcomes and the secondary target was patient outcomes.

## SUMMARY OF EVIDENCE FOR CANCER TRIALS

The disease course for cancer and memory related conditions are often different, and the family’s potential role in helping to improve outcomes reflects these differences. In addition to the side effects and consequences of treatment, cancer patients and their families are often faced with significant changes and challenges in their relationships and uncertainty about how the disease and their lives will progress. With the majority of trials including patients with early or mid-staged cancers, the family-involved interventions focused on improving quality of life and functional status, reducing depression and anxiety, managing symptoms, and adjusting to one’s intimate relationship.

We found some evidence that favors family-involved interventions over usual cancer care for improving patient symptoms and depression/anxiety. We also found some evidence, albeit weak, that family-involved interventions are superior to ones that are patient-focused or provide only health education or psychoeducation in improving symptoms. The evidence suggests that family involved interventions designed for specific sub-groups (e.g., cancer patients with late stage cancer, couples in newer relationships, hospice patients) may be more effective at improving a broad range of cancer-related symptoms and depression/anxiety than usual care. Likewise, family interventions teaching a specific skill (e.g., reflexology) to address a symptom or problem (e.g., pain) may be more effective for improving symptoms than providing general support or education. However, we recommend that these findings be viewed with caution. All but two of the 27 trials were of poor or fair quality, and although a broad range of symptoms improved within a single trial (e.g., sexual functioning, side effect severity, symptom-related distress), we found little evidence across trials that specific symptoms commonly associated with cancer and cancer treatment, such as pain, fatigue, or nausea improved. Across all trials we also did not find a strong evidence base supporting family interventions to improve overall quality of life or components of quality of life (including physical, general psychological, and social functioning) or relationship adjustment.

## SUMMARY OF EVIDENCE FOR MEMORY TRIALS

Family roles can be significantly disrupted when a family member with a memory disorder begins to show signs of disease progression. Unlike cancer, however, there is little ambiguity about the unalterable course of these diseases. Families are typically aware that patient functioning will decline over time and not improve. Compared to the cancer trials, family interventions tended to target more traditional forms of caregiving, concentrating more on maintaining or improving patient quality of life and managing problem behaviors as they evolve than on adjusting to changes in roles, relationships, and overall functional status.

Like the cancer trials, for memory-related conditions we also found weak evidence to suggest that family-involved interventions improve patient outcomes more than usual care. The strength of evidence for family-involved interventions improving outcomes over patient-focused or other health education or psychoeducation interventions for patients with memory-related disorders is also low. Our findings are unfortunate in that they do not provide clear answers to how families can improve cognitive functioning or symptom management or reduce health care utilization. However, we did find some evidence that suggests that targeted interventions to groups of patients with specific symptoms (e.g., depression) may be more effective in managing and controlling symptoms and reducing depression than usual care and that unique interventions that included targeted strategies to help families control or manage specific symptoms (e.g., agitation, affect) were more effective than usual care. Data were insufficient to suggest that one type of intervention is superior to another at improving most patient outcomes, although for symptom control, a number of trials, all narrowly focused to change specific symptoms (e.g., insomnia, incontinence), did show some significant improvement over alternative interventions.

## CONCLUSIONS

Our findings echo a previous review that used similar criteria to ours.5 In that review, Martire reported that studies were very heterogeneous and that the evidence suggested that family interventions improved depression, but had little effect on anxiety and no effect on physical disability. It is rather disappointing that our review, conducted 10 years after the Martire review, has similar conclusions as it casts doubt on whether progress has been made at improving patient outcomes in spite of the increasingly important role families are taking in patient care. A recent review by Hartmann6 is more heartening. Compared to usual care, family psychoeducation or family or couple therapy had small but significant effects on the physical and mental health of patients with cardiovascular disease/stroke and HIV/AIDS and on mental health for cancer patients. It is possible, therefore, that our conclusions are specific only to cancer and memory-related disorders and cannot be generalized to other conditions. Some have suggested that family psychosocial interventions of any kind may lessen patient psychological distress,7, 8 but our findings comparing usual care or wait list controls to family-involved interventions, suggest this is not the case. Others have suggested that time alone may be a factor in reducing some negative outcomes or improving positive outcomes among patients.9 Given the lack of long-term outcome data, we cannot determine if this is true, but a number of our studies reported that even if differences were not significant, those in the intervention group experienced greater improvement or less decline than those in the control group.10–12

## LIMITATIONS

Our review has a number of limitations. First, although we had a large number of RCTs to review, it is possible that by including evidence from rigorous observational evidence we would have different conclusions, although these studies would likely also introduce different biases. Second, a number of studies in our review were primarily designed to improve family member outcomes (e.g., reducing family member burden), not patient outcomes. This may have affected how the data were reported and the strength of the evidence for single trials. The REACH trials, for example, have shown significant improvements in caregiver55, 76, 77 outcomes, but patient outcomes reviewed for this report were not consistently different than control conditions. It is possible that effective interventions targeting caregiver outcomes may subsequently benefit patients, but that the effect on caregivers must be large enough that any diluting of the benefit that is transmitted from caregivers to patients is perceptible. Third, we limited our review to two conditions: cancer and memory-related disorders. Expanding our review to include other conditions may affect our conclusions as well, although we expect it would not given the number of studies with other conditions we identified in our original search and the consistency of findings with the review by Martire,5 who included multiple conditions. Fourth, our review did not include any large-scale interventions or program evaluations of family involved interventions that are comparable to family member programs that VHA has recently implemented (e.g., Caregiver Hotline; OEF/OIF Caregiver Support Program, etc.). None of the interventions we reviewed tested the impact on patients of supporting caregivers financially or in providing access to health care and health services. Therefore, we have insufficient evidence to determine if current programs targeting family members will, in fact, affect short- or long-term patient outcomes. This is an area that needs further study.

## RECOMMENDATIONS FOR FUTURE RESEARCH

Based on our findings, we have a number of recommendations to consider. First, our review suggests that general interventions for families may not improve patient outcomes, but family interventions targeting specific conditions, behaviors, or symptoms will likely be more effective, particularly when resources are limited. Second, other studies have shown that family interventions can reduce burden.3 However, it remains unclear if by reducing family burden, families can provide better care which then, in turn, improves patient outcomes. Future research that can rigorously test this question is needed. Understanding the link between family health and patient health is critical for understanding whether separate interventions should address family issues and patient issues, or if investing in family interventions will provide downstream improvements in patient outcomes. Third, given the increasing role that Veterans’ families and families, in general, have in the treatment of chronic disease, it is critical that future research is undertaken to fill the gaps that our review has highlighted and build on the promising strengths we have identified. Identifying sub-groups (e.g., by disease stage or severity of condition, relationship between patient and family member, education level, etc.) should be considered for each condition in order to verify if tailoring interventions is more advantageous than a one-size-fits-all intervention. These types of trials would provide important data for making both policy and clinically meaningful decisions about which interventions to implement to whom and at what stage in the disease course. Fourth, although the evidence is inconclusive about whether telephone or web-based counseling or other supportive programs that rely on technology are as effective as other forms of counseling, they have potential benefit to rural or home-bound family and patients, families who are poor and have few means, and families who have little access to other forms of support. Methodologically rigorous research will be important to pursue in future research in order to assess whether the benefit of these types of programs are equivalent to usual care and in-person programs. In future research, researchers should attend to issues of study quality, including blinding, allocation concealment, descriptions of dropouts, and intent to treat analyses. Outcome data should be reported post-treatment for each condition for direct group comparison and, when feasible, longer term outcomes should be included to assess intervention sustainability. Additionally, researchers should report study subgroups, including relationship of family member to patient and disease stage. Finally, researchers should consider either reducing the number of comparisons or conditions to preserve statistical power or increasing study sample size as much as it is feasible.

VHA has taken broad and important steps to integrate families into the care of Veterans and to support them in their role. Research examining the effects of family interventions on outcomes of patients with cancer and memory-related disorders within the US since 1995 is underdeveloped. There is both little and weak evidence to suggest that general family interventions improve outcomes for these patients; sub-groups of family members and patient with specific needs may benefit more than others. Customizing and targeting family-involved interventions to specific sub-groups may be the most efficient way to improve patient outcomes.