# REFERENCES

1 Thompson CA, Spilsbury K, Hall J, Birks Y, Barnes C, Adamson J. Systematic review of information and support interventions for caregivers of people with dementia. BMC Geriatrics. 2007;7:18. [pmid: 17662119].
2 Goy E, Kansagara D, Freeman M. A systematic evidence review ofinterventions for non-professional caregivers of individuals with dementia. Washington (DC). Department of Veterans Affairs. 2010. October. Available from: http://www.ncbi.nlm.nih.gov/books/NBK49194/.
3 Sorensen S, Pinquart M, Duberstein P. How effective are interventions with caregivers? An updated meta-analysis. Gerontologist. Jun. 2002;42(3):356-72. [pmid: 12040138].
4 Visser-Meily A, van Heugten C, Post M, Schepers V, Lindeman E. Intervention studies for caregivers of stroke survivors: a critical review. Patient Educ Couns. Mar. 2005;56(3):257-67. [pmid: 15721967].
5 Martire LM, Lustig AP, Schulz R, Miller GE, Helgeson VS. Is it beneficial to involve a family member? A meta-analysis of psychosocial interventions for chronic illness. Health Psychol. Nov. 2004;23(6):599-611. [pmid: 15546228].
6 Hartmann M, Bazner E, Wild B, Eisler I, Herzog W. Effects of interventions involving the family in the treatment of adult patients with chronic physical diseases: a meta-analysis. Psychother Psychosom. 2010;79(3):136-48. [pmid: 20185970].
7 Donnelly JM, Kornblith AB, Fleishman S, et al. A pilot study of interpersonal psychotherapy by telephone with cancer patients and their partners. Psycho-Oncology. Jan–Feb. 2000;9(1):44-56. [pmid: 10668059].
8 Manne SL, Ostroff JS, Winkel G, et al. Couple-focused group intervention for women with early stage breast cancer. J Consult Clin Psychol. Aug. 2005;73(4):634-46. [pmid: 16173851].
9 Badger T, Segrin C, Dorros SM, Meek P, Lopez AM. Depression and anxiety in women with breast cancer and their partners. Nurs Res. Jan–Feb. 2007;56(1):44-53. [pmid: 17179873].
10 Gitlin LN, Winter L, Dennis MP, Hodgson N, Hauck WW. A biobehavioral home-based intervention and the well-being of patients with dementia and their caregivers: The COPE randomized trial. JAMA. 2010;304(9):983-91. [pmid: 20810376].
11 Camberg L, Woods P, Ooi WL, et al. Evaluation of Simulated Presence: a personalized approach to enhance well-being in persons with Alzheimer’s disease. J Am Geriatr Soc. Apr. 1999;47(4):446-52. [pmid: 10203120].
12 Teri L, Gibbons LE, McCurry SM, et al. Exercise plus behavioral management in patients with alzheimer disease: A Randomized Controlled Trial. JAMA. 2003;290(15):2015-22. [pmid: 14559955].
13 Meis L, Griffin J, Greer N, et al. Family involved psychosocial treatments for adult mental health conditions: A review of the evidence. Washington (DC). Department of Veterans Affairs. 2012. Feb. Available from: http://www.ncbi.nlm.nih.gov/books/NBK117205.
14 Martire LM, Schulz R, Helgeson VS, Small BJ, Saghafi EM. Review and meta-analysis of couple-oriented interventions for chronic illness. Ann Behav Med. Dec. 2010;40(3):325-42. [pmid: 20697859].
15 Fisher L, Weihs KL. Can addressing family relationships improve outcomes in chronic disease? Report of the National Working Group on Family-Based Interventions in Chronic Disease. J Fam Pract. Jun. 2000;49(6):561-6. [pmid: 10923558].
16 Torti FM Jr, Gwyther LP, Reed SD, Friedman JY, Schulman KA. A multinational review of recent trends and reports in dementia caregiver burden. Alzheimer Dis Assoc Disord. Apr–Jun. 2004;18(2):99-109. [pmid: 15249854].
17 Corbett A, Stevens J, Aarsland D, et al. Systematic review of services providing information and/or advice to people with dementia and/or their caregivers. Int J Geriatr Psychiatry. Jun. 2012;27(6):628-36. [pmid: 22038644].
18 Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0. [updated March 2011]. The Cochrane Collaboration. 2011. Available from www.cochrane-handbook.org.
19 Cohen J. Statistical Power Analysis for the Behavioral Sciences. 2nd ed. Hillsdale, NJ. Lawrence Erlbaum Assoc. 1988.
20 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
21 Badger TA, Segrin C, Figueredo AJ, et al. Psychosocial interventions to improve quality of life in prostate cancer survivors and their intimate or family partners. Qual Life Res. Aug. 2011;20(6):833-44. [pmid: 21170682].
22 Giesler RB, Given B, Given CW, et al. Improving the quality of life of patients with prostate carcinoma: a randomized trial testing the efficacy of a nurse-driven intervention. Cancer. Aug. 15. 2005;104(4):752-62. [pmid: 15986401].
23 Northouse LL, Mood DW, Schafenacker A, et al. Randomized clinical trial of a family intervention for prostate cancer patients and their spouses. Cancer. Dec. 15. 2007;110(12):2809-18. [pmid: 17999405].
24 Mishel MH, Belyea M, Germino BB, et al. Helping patients with localized prostate carcinoma manage uncertainty and treatment side effects: nurse-delivered psychoeducational intervention over the telephone. Cancer. Mar. 15. 2002;94(6):1854-66. [pmid: 11920549].
25 Campbell LC, Keefe FJ, McKee DC, et al. Prostate cancer in African Americans: relationship of patient and partner self-efficacy to quality of life. J Pain Symptom Manage. Nov. 2004;28(5):433-44. [pmid: 15504620].
26 Campbell LC, Keefe FJ, Scipio C, et al. Facilitating research participation and improving quality of life for African American prostate cancer survivors and their intimate partners. A pilot study of telephone-based coping skills training. Cancer. Jan. 15. 2007;109(2 Suppl):414-24. [pmid: 17173280].
27 Manne SL, Kissane DW, Nelson CJ, Mulhall JP, Winkel G, Zaider T. Intimacy-enhancing psychological intervention for men diagnosed with prostate cancer and their partners: a pilot study. J Sex Med. Apr. 2011;8(4):1197-209. [pmid: 21210958].
28 McCorkle R, Siefert ML, Dowd MFE, Robinson JP, Pickett M. Effects of advanced practice nursing on patient and spouse depressive symptoms, sexual function, and marital interaction after radical prostatectomy. Urol Nurs. Feb. 2007;27(1):65-77. [pmid: 17390930].
29 Northouse L, Kershaw T, Mood D, Schafenacker A. Effects of a family intervention on the quality of life of women with recurrent breast cancer and their family caregivers. Psycho-Oncology. 2005;14(6):478-91. [pmid: 15599947].
30 Budin WC, Hoskins CN, Haber J, et al. Breast cancer: Education, counseling, and adjustment among patients and partners: A randomized clinical trial. Nurs Res. 2008;57(3):199-213. [pmid: 18496106].
31 Baucom DH, Porter LS, Kirby JS, et al. A couple-based intervention for female breast cancer. Psycho-Oncology. Mar. 2009;18(3):276-83. [pmid: 18702064].
32 Kayser K, Feldman BN, Borstelmann NA, Daniels AA. Effects of a randomized couple-based intervention on quality of life of breast cancer patients and their partners. Soc Work Res. 2010;34(1):20-32.
33 Manne S, Ostroff JS, Winkel G. Social-cognitive processes as moderators of a couple-focused group intervention for women with early stage breast cancer. Health Psychol. Nov. 2007;26(6):735-44. [pmid: 18020846].
34 Keefe FJ, Ahles TA, Sutton L, et al. Partner-guided cancer pain management at the end of life: a preliminary study. J Pain Symptom Manage. Mar. 2005;29(3):263-72. [pmid: 15781177].
35 Kozachik SL, Given CW, Given BA, et al. Improving depressive symptoms among caregivers of patients with cancer: results of a randomized clinical trial. Oncol Nurs Forum. Aug. 2001;28(7):1149-57. [pmid: 11517848].
36 Nezu AM, Nezu CM, Felgoise SH, McClure KS, Houts PS. Project Genesis: assessing the efficacy of problem-solving therapy for distressed adult cancer patients. J Consult Clin Psychol. Dec. 2003;71(6):1036-48. [pmid: 14622079].
37 Blanchard CG, Toseland RW, McCallion P. The effects of a problem-solving intervention with spouses of cancer patients. J Psychosoc Oncol. 1996;14(2):1-21.
38 Meyers FJ, Carducci M, Loscalzo MJ, Linder J, Greasby T, Beckett LA. Effects of a problem-solving intervention (COPE) on quality of life for patients with advanced cancer on clinical trials and their caregivers: Simultaneous care educational intervention (SCEI): Linking palliation and clinical trials. J Palliat Med. Apr. 2011;14(4):465-73. [pmid: 21413846].
39 Kurtz ME, Kurtz J, Given CW, Given B. A randomized, controlled trial of a patient/caregiver symptom control intervention: Effects on depressive symptomatology of caregivers of cancer patients. J Pain Symptom Manage. 2005;30(2):112-22. [pmid: 16125026].
40 McMillan SC, Small BJ. Using the COPE intervention for family caregivers to improve symptoms of hospice homecare patients: a clinical trial. Oncol Nurs Forum. Mar. 2007;34(2):313-21. [pmid: 17573295].
41 Schover LR, Canada AL, Yuan Y, et al. A randomized trial of internet-based versus traditional sexual counseling for couples after localized prostate cancer treatment. Cancer. Jan. 15. 2012;118(2):500-9. [pmid: 21953578].
42 Given B, Given CW, Sikorskii A, Jeon S, Sherwood P, Rahbar M. The impact of providing symptom management assistance on caregiver reaction: Results of a randomized trial. J Pain Symptom Manage. 2006;32(5):433-43. [pmid: 17085269].
43 Canada AL, Neese LE, Sui D, Schover LR. Pilot intervention to enhance sexual rehabilitation for couples after treatment for localized prostate carcinoma. Cancer. Dec. 15. 2005;104(12):2689-700. [pmid: 16294343].
44 Gustafson DH, DuBenske LL, Namkoong K, et al. An eHealth system supporting palliative care for patients with nonsmall cell lung cancer: A randomized trial. Cancer. 2013. Jan. 25. Epub ahead of print.
45 Porter LS, Keefe FJ, Garst J, et al. Caregiver-assisted coping skills training for lung cancer: Results of a randomized clinical trial. J Pain Symptom Manage. 2011;41(1):1-13. [pmid: 20832982].
46 Porter LS, Keefe FJ, Baucom DH, et al. Partner-assisted emotional disclosure for patients with gastrointestinal cancer: results from a randomized controlled trial. Cancer. Sep. 15. 2009;115(18 Suppl):4326-38. [pmid: 19731357].
47 Mokuau N, Braun KL, Wong LK, Higuchi P, Gotay CC. Development of a family intervention for Native Hawaiian women with cancer: a pilot study. Soc Work. Jan. 2008;53(1):9-19. [pmid: 18610817].
48 Stephenson NLN, Swanson M, Dalton J, Keefe FJ, Engelke M. Partner-delivered reflexology: effects on cancer pain and anxiety. Oncol Nurs Forum. Jan. 2007;34(1):127-32. [pmid: 17562639].
49 Wray LO, Shulan MD, Toseland RW, Freeman KE, Vasquez BE, Gao J. The effect of telephone support groups on costs of care for veterans with dementia. Gerontologist. Oct. 2010;50(5):623-31. [pmid: 20507926].
50 Ostwald SK, Hepburn KW, Caron W, Burns T, Mantell R. Reducing caregiver burden: a randomized psychoeducational intervention for caregivers of persons with dementia. Gerontologist. Jun. 1999;39(3):299-309. [pmid: 10396888].
51 Burns R, Nichols LO, Martindale-Adams J, Graney MJ, Lummus A. Primary care interventions for dementia caregivers: 2-year outcomes from the REACH study. Gerontologist. Aug. 2003;43(4):547-55. [pmid: 12937333].
52 Mittelman MS, Haley WE, Clay OJ, Roth DL. Improving caregiver well-being delays nursing home placement of patients with Alzheimer disease. Neurology. Nov. 14. 2006;67(9):1592-99. [pmid: 17101889].
53 Robison J, Curry L, Gruman C, Porter M, Henderson CR Jr, Pillemer K. Partners in caregiving in a special care environment: Cooperative communication between staff and families on dementia units. Gerontologist. 2007;47(4):504-14. [pmid: 17766671].
54 Mittelman MS, Roth DL, Haley WE, Zarit SH. Effects of a caregiver intervention on negative caregiver appraisals of behavior problems in patients With Alzheimer’s disease: Results of a randomized trial. J Gerontol B Psychol Sci Soc Sci. 2004;59B(1):P27-34. [pmid: 14722336].
55 Belle SH, Burgio L, Burns R, et al. Enhancing the quality of life of dementia caregivers from different ethnic or racial groups: a randomized, controlled trial. Ann Intern Med. Nov. 21. 2006;145(10):727-38. [pmid: 17116917].
56 Bass DM, Clark PA, Looman WJ, McCarthy CA, Eckert S. The Cleveland Alzheimer’s managed care demonstration: Outcomes after 12 months of implementation. Gerontologist. 2003;43(1):73-85. [pmid: 12604748].
57 Gitlin LN, Corcoran M, Winter L, Boyce A, Hauck WW. A randomized, controlled trial of a home environmental intervention: effect on efficacy and upset in caregivers and on daily function of persons with dementia. Gerontologist. Feb. 2001;41(1):4-14. [pmid: 11220813].
58 Jirovec MM, Templin T. Predicting success using individualized scheduled toileting for memory-impaired elders at home. Res Nurs Health. Feb. 2001;24(1):1-8. [pmid: 11260580].
59 Brodaty H, Mittelman M, Gibson L, Seeher K, Burns A. The effects of counseling spouse caregivers of people with Alzheimer disease taking donepezil and of country of residence on rates of admission to nursing homes and mortality. Am J Geriatr Psychiatry. Sep. 2009;17(9):734-43. [pmid: 19705519].
60 Martin-Cook K, Davis BA, Hynan LS, Weiner MF. A randomized, controlled study of an Alzheimer’s caregiver skills training program. Am J Alzheimers Dis Other Demen. 2005;20(4):204-10. [pmid: 16136843].
61 McCurry SM, Gibbons LE, Logsdon RG, Vitiello MV, Teri L. Nighttime insomnia treatment and education for Alzheimer’s disease: A randomized, controlled trial. J Am Geriatr Soc. 2005;53(5):793-802. [pmid: 15877554].
62 Quayhagen MP, Quayhagen M, Corbeil RR, et al. Coping with dementia: Evaluation of four non pharmacologic interventions. Int Psychogeriatr. 2000;12(2):249-65. [pmid: 10937544].
63 Logsdon RG, Pike KC, McCurry SM, et al. Early-stage memory loss support groups: outcomes from a randomized controlled clinical trial. J Gerontol B Psychol Sci Soc Sci. Nov. 2010;65(6):691-7. [pmid: 20693265].
64 Gonyea JG, O’Connor MK, Boyle PA. Project CARE: A randomized controlled trial of a behavioral intervention group for Alzheimer’s disease caregivers. Gerontologist. 2006;46(6):827-32. [pmid: 17169938].
65 Burgener SC, Bakas T, Murray C, Dunahee J, Tossey S. Effective caregiving approaches for patients with Alzheimer’s disease. Geriatr Nurs. May–Jun. 1998;19(3):121-6. [pmid: 9708136].
66 Teri L, McCurry SM, Logsdon R, Gibbons LE. Training community consultants to help family members improve dementia care: a randomized controlled trial. Gerontologist. Dec. 2005;45(6):802-11. [pmid: 16326662].
67 Wright LK, Litaker M, Laraia MT, DeAndrade S. Continuum of care for Alzheimer’s disease: a nurse education and counseling program. Issues Ment Health Nurs. Apr–May. 2001;22(3):231-52. [pmid: 11885210].
68 McCallion P, Toseland RW, Freeman K. An evaluation of a family visit education program. J Am Geriatr Soc. Feb. 1999;47(2):203-14. [pmid: 9988292].
69 Gerdner LA, Buckwalter KC, Reed D. Impact of a psychoeducational intervention on caregiver response to behavioral problems. Nurs Res. Nov–Dec. 2002;51(6):363-74. [pmid: 12464756].
70 Teri L, Logsdon RG, Uomoto J, McCurry SM. Behavioral treatment of depression in dementia patients: a controlled clinical trial. J Gerontol B Psychol Sci Soc Sci. Jul. 1997;52(4):P159-66. [pmid: 9224439].
71 Chang BL. Cognitive-behavioral intervention for homebound caregivers of persons with dementia. Nurs Res. May–Jun. 1999;48(3):173-82. [pmid: 10337848].
72 Bourgeois MS, Schulz R, Burgio LD, Beach S. Skills training for spouses of patients with Alzheimer’s disease: Outcomes of an intervention study. J Clin Geropsychol. Jan. 2002;8(1):53-73.
73 Gitlin LN, Winter L, Corcoran M, Dennis MP, Schinfeld S, Hauck WW. Effects of the home environmental skill-building program on the caregiver-care recipient dyad: 6-month outcomes from the Philadelphia REACH Initiative. Gerontologist. Aug. 2003;43(4):532-46. [pmid: 12937332].
74 Gitlin LN, Winter L, Burke J, Chernett N, Dennis MP, Hauck WW. Tailored activities to manage neuropsychiatric behaviors in persons with dementia and reduce caregiver burden: A randomized pilot study. Am J Geriatr Psychiatry. 2008;16(3):229-39. [pmid: 18310553].
75 Gitlin LN, Winter L, Dennis MP, Hodgson N, Hauck WW. Targeting and managing behavioral symptoms in individuals with dementia: A randomized trial of a nonpharmacological intervention. J Am Geriatr Soc. 2010;58(8):1465-74. [pmid: 20662955].
76 Elliott AF, Burgio LD, Decoster J. Enhancing caregiver health: findings from the resources for enhancing Alzheimer’s caregiver health II intervention. J Am Geriatr Soc. Jan. 2010;58(1):30-37. [pmid: 20122038].
77 Mausbach BT, Coon DW, Depp C, et al. Ethnicity and time to institutionalization of dementia patients: a comparison of Latina and Caucasian female family caregivers. J Am Geriatr Soc. Jul. 2004;52(7):1077-84. [pmid: 15209644].