# METHODS

## TOPIC DEVELOPMENT

Sonja Batten, PhD, and the Office of Mental Health Services nominated this topic to learn what the benefits to a Veteran’s medical outcomes are if their family members are included in treatment or care and if there is any evidence that providing support services to a family member improves outcomes or effectiveness of the treatment that is being provided to a Veteran who is receiving care for a medical condition.

## SEARCH STRATEGY

Trained research personnel searched MEDLINE (Ovid) and PsycINFO for randomized controlled trials (RCTs) and systematic reviews published 1980 to December, 2012 using the following search terms: family, couples, home nursing, legal guardians, couple therapy, family therapy, or marital therapy. The complete search strategy is presented in Appendix A. Additional citations were identified from systematic reviews, reference lists of retrieved articles, and suggestions made by our technical expert panel members and peer reviewers.

## STUDY SELECTION

Titles, abstracts, and articles were reviewed by researchers trained in the critical analysis of literature. Full text versions of potentially eligible articles were retrieved for review. Although our search identified studies of patients with both mental health and physical health conditions published from 1980 to the present, due to the volume of eligible articles identified by our search and previous work in this area, we narrowed our primary inclusion criteria at the time of full-text review to include RCTs or systematic reviews or meta-analyses of RCTs meeting the following criteria:

- Conducted in the United States,
- Involved patients at least 18 years old with a physical health condition,
- Included an intervention that involves family members or caregivers of the adult patient (patient may or may not be present for the intervention),
- Reported patient outcomes of interest, as outlined in the analytic framework (Figure 1),
- Included a control group; control group may be usual care/wait list control or an alternative active treatment (e.g., individually-oriented treatment or another family/couple-oriented intervention), and
- Published in a peer-reviewed publication after 1995.

After the full-text review, we applied a secondary exclusion criterion to further refine the scope and narrow the search. This criterion included only studies that targeted patients with one of two conditions – cancer or memory-related conditions. These conditions made up the majority of the studies reviewed, providing the largest body of evidence from which we could synthesize the evidence.

## DATA ABSTRACTION

We abstracted study characteristics, patient characteristics, and outcomes separately for cancer studies and memory-related studies. Data were abstracted by one study team member (investigators or trained research associates) and verified by another, all under the supervision of the Principal Investigator.

We abstracted the following study characteristics for each included study: author, date of publication, funding source, patient characteristics (gender, age, race/ethnicity, marital status, education, Veteran status), family member characteristics (gender, age, race/ethnicity, marital status, education, relationship to patient), recruitment method, inclusion and exclusion criteria (physical health condition, how the condition was assessed, family/caregivers involvement, and other specific inclusion and exclusion criteria), treatment groups, intervention characteristics (format, whether a specific protocol was used, number of sessions, treatment length, approach, and treatment integrity), outcomes assessed, and study quality (reports of allocation concealment, blinding, analysis approach, description of withdrawals).

We focused on the patient- and family-centered outcomes outlined above. For cancer, our primary outcomes of interest were: overall quality of life; the components of quality of life (physical, mental health, and social functioning); and symptom control/management. Secondary outcomes included depression/anxiety, utilization (including hospitalization and institutionalization), and relationship adjustment. For memory disorders, we assessed similar outcomes as for cancer but included cognitive functioning instead of general psychological functioning. Only outcomes that were assessed using previously published scales or measures or had clear end-points (e.g., death, hospitalization) were included. In order to determine both immediate and long-term benefits of the intervention, we captured, whenever possible, data at two time-points: post-intervention ([underlined: +]1 month) and at least 6 months post-intervention. For studies with multiple assessments more than 6 months post intervention, the last available assessment was abstracted.

## QUALITY ASSESSMENT

We assessed the risk of bias for each trial and used this assessment as the basis for rating the trial’s quality. Using established criteria for evaluating risk of bias in RCTs, we considered whether: the intervention allocation was concealed; participants, interventionists, or health care providers were blinded to treatment allocation; intention-to-treat (ITT) analyses were used; withdrawals and dropouts by group assignment were adequately described; and if the treatment was monitored for quality and consistency (i.e., treatment integrity). We rated trials as good, fair, or poor quality and considered allocation concealment and blinding (of outcome assessors at a minimum) as critical elements for a good quality trial.18

A good quality trial (low risk of bias) indicated that the trial reported adequate allocation concealment, a minimum of single blinding (participants or investigators or assessors are blinded), and that either intent-to-treat analysis was conducted or clear reasons for dropouts/attrition by group were provided. A fair quality trial (moderate risk of bias) was one in which allocation concealment and blinding criteria were either met or unclear and no more than one of the remaining criterion (ITT, withdrawals) were unmet. A trial with adequate allocation concealment that did not meet other domains, or did not make clear whether other domains were met, was rated as fair. Trials were rated poor quality (high risk of bias) if the trial had inadequate allocation concealment or no blinding and/or clearly met only one of the established risk of bias domains.

## DATA SYNTHESIS

We analyzed studies by comparing their characteristics, methods, and findings. Few pooled analyses of data were possible due to heterogeneity of populations, interventions and outcomes across studies; therefore, most findings were summarized narratively. When reported, intervention effect sizes from trials were extracted. If effect sizes in a trial were not reported but sample size, standard deviation, and mean scores were, we calculated intervention effect sizes for each outcome in order to compare across studies. We compiled a summary of findings by condition for each question, and then summarized findings across intervention categories. If the effect size was significant (the confidence interval did not include 0), we considered this a significant effect in our summary, even if the authors report null findings. We considered Cohen’s guide for interpreting effect sizes (i.e., d of 0.2 = small effect, 0.5 = medium effect, 0.8 = large effect) when evaluating outcome data.19

## STRENGTH OF EVIDENCE

We determined the strength of evidence for each outcome based on all studies that assessed that outcome. Using criteria outlined by Owens et al.,20 (see Appendix B), we rated the strength of evidence for each outcome using the following grades: 1) high confidence indicated that further research is very unlikely to change the confidence in the estimate of effect, meaning that the evidence reflects the true effect; 2) moderate confidence denoted that further research may change our confidence in the estimate of effect and may change the estimate; 3) low confidence indicated that further research is very likely to have an important impact on the confidence in the estimate of effect and is likely to change the estimate, meaning that there is low confidence that the evidence reflects the true effect; and 4) insufficient, indicating that the evidence was unavailable or did not permit a conclusion.

## PEER REVIEW

A draft version of this report was reviewed by technical experts and clinical leadership. Reviewer comments were addressed and our responses are incorporated in the final report (Appendix C).