# INTRODUCTION

## BACKGROUND

Since 2008, two federal laws have been signed that have established or expanded the VA’s authority to provide clinical and support services to families of Veterans. The first, signed into law on October 10, 2008, allows the VA to provide enhanced family mental health services, such as consultation, professional counseling, marriage and family counseling, and training to families of patients with Service Connected and Non-Service Connected injuries or conditions when: 1) no Veteran treatment would otherwise occur without the family member’s involvement; 2) the Veteran’s treatment would be less or not effective without family member’s involvement; or 3) the treatment can be delivered most efficiently when the family member is included in treatment (Public Law 110–387: Veterans’ Mental Health and Other Care Improvements Act of 2008, Section 301, amending title 38 of United States Code (U.S.C.) § 1701(5)(B) and 38 U.S.C. § 1782a and b). The second law, signed in May, 2010, allows the VA authority to provide these same services and comprehensive support services to family caregivers of Veterans and also directs the VA to provide additional benefits (e.g., financial stipends and health care benefits) to eligible caregivers who provide essential care to Veterans severely injured in Operation Iraqi Freedom (OIF) and Operation Enduring Freedom (OEF) (Public Law 111–163: Caregivers and Veterans Omnibus Health Services Act). With this new authority to extend some services to family members, and the VA’s adoption of a patient-centered medical home model in primary care, a model that, among other things, aims to integrate family involvement, the VA now has the potential to adopt or integrate efficacious family-involved interventions to improve Veterans’ outcomes.

Our previous review13 was a synthesis of evidence of family-involved interventions for improving Veterans’ mental health outcomes. In this review we sought to synthesize the evidence of family-involved interventions aimed at improving adult patients’ physical health outcomes, in particular, for cancer and memory-related conditions. We limited our focus to family members caring for those with cancer and memory-related conditions since the majority of studies fitting our criteria examined one of these two conditions.

To date, the majority of reviews on family interventions have concentrated on [underlined: family] or [underlined: caregiver] health and well-being1–4 focusing on interventions developed to reduce the physical and psychosocial toll that is associated with providing care and support. A large proportion of these interventions are also targeted to parents of children with chronic disease, illness, or disabilities. The few reviews of family intervention effects on adult patient outcomes have had a narrow scope, including one with only couple-oriented interventions, thus excluding studies with non-spouse family or caregivers,14 and one with family or couple therapy interventions compared to a “standard treatment” comparison group, thus excluding any comparative effectiveness of interventions.6

## DEFINITIONS OF KEY CONCEPTS OF FAMILY AND OUTCOMES

Study settings often determine how the person with the condition is described (e.g., care recipient, resident, spouse). Since participants were included in trials based on their diagnosis, we use the term “patient” to describe the person with dementia or cancer.

The literature uses a number of different terms to describe those who provide unpaid help and support to patients: family, informal caregivers, care partners, and support network. For convenience, we use the term “family member” to describe all those, related and non-related, who provide direct care and support to patients with cancer or memory-related disorders. Given the broad range of care and support needed by those with cancer and memory-related conditions, we opted for this more general term, although we concede that not all participants were required to be related to the patient.

We examined the effect of family-involved interventions on five outcomes: quality of life, depression/anxiety, symptom control, health care utilization, and relationship adjustment. Quality of life was defined as overall quality of life (i.e., global quality of life) and then further conceptualized to include functional status, including physical functioning (e.g., activities of daily living and instrumental activities of daily living); general psychological functioning that does not directly correspond with mental health conditions or diagnoses in the Diagnostic and Statistical Manual (DSM) (e.g., distress, psychological well-being); cognitive functioning (e.g., memory capacity, problem solving abilities); and social functioning (e.g., social and family well-being). Depression/anxiety included reports of depressive symptoms or anxiety using standardized assessments. Symptom control or management included reports of any physical symptoms or side effects associated with treatment or disease progression (e.g., for cancer: pain and sexual functioning; for memory-related disorders: agitation, wandering, or other problem behaviors). Utilization included all types of health care utilization, including hospitalization, institutionalization, or emergency room visits. Relationship adjustment included broad measures of general relationship adjustment, relationship quality, or relationship functioning.

## CATEGORIZATION OF INTERVENTIONS

Disease symptoms, treatment side effects and consequences of disease progression are often the targets of patient-centered interventions. Because both the interventions and the targets of the interventions are unique and differ by condition, we reviewed types of interventions and targets of the intervention separately. To further understand whether certain types of interventions had more evidence than others, we first reviewed the study methods of all the selected trials and then grouped similar interventions into similar categories by condition (cancer or memory-related conditions). The intervention categories are similar to categories conceptualized by Fisher,15 although two additional categories (telephone or web-based counseling and unique interventions) were included.

For cancer studies, each trial was grouped into one of five categories: 1) telephone or web-based counseling, where, in at least one intervention arm, telephone or web-based counseling was provided separately for family members and patient; 2) behavioral couples therapy or adaptations of cognitive behavior therapy; 3) training for family members to manage or control specific patient symptoms; 4) interventions that, in addition to training families to effectively manage patient symptoms or behaviors, also included family support or counseling; and 5) unique interventions with unique intervention targets.

Interventions for families of those with memory disorders were grouped into one of three categories: 1) training families to change or manage patient behavior, 2) interventions that provided support or counseling for family members and trained them to effectively manage patient symptoms or behaviors, and 3) unique interventions with unique intervention targets.

## OBJECTIVES

Using our analytic framework to guide our approach (Figure 1), we conducted a systematic review of the published randomized controlled trials (RCTs) evaluating whether family involved interventions improve [underlined: patient outcomes] (i.e., efficacy) and whether one specific family involved intervention is better than an alternative one (i.e., specificity or comparative effectiveness). We specifically examined the effects of family-involved interventions on the [underlined: patients], not on the family members. We assessed if there is evidence that interventions targeted at family members only or both family members and adult patients improve the patients’ outcomes.

Figure 1 Analytic Framework

Given the previous work in this area, we focused our review only on those studies conducted after 1995. Several studies have shown social and cultural norms and resources for family support vary across countries;16, 17 therefore, we limited the search to articles conducted in the United States and to articles published in English. To assure comparability to the adult population that the VA serves, we included only studies involving subjects over age 18 and limited our review to improvements in quality of life, depression/anxiety, symptom management/control, health care utilization and relationship adjustment. Our analytic framework, shown in Figure 1, outlines our target population, and our interventions, comparators, and outcomes of interest. We review the evidence on family involved interventions compared to usual care or wait list and also to individually-focused interventions or an alternative family-involved intervention.

Our key questions were:

Key Question #1 What are the benefits of family and caregiver psychosocial interventions for adult patients with cancer or memory-related disorders compared to usual care or wait list?
  a. What are the harms of these interventions?
  b. Do these benefits/harms vary by type of intervention, health condition, or patient functional status, or across outcomes?
Key Question #2 What are the benefits of one family or caregiver oriented psychosocial intervention compared to either: 1) a patient-directed intervention or 2) another alternative family-oriented intervention in improving outcomes for adult patients with cancer or memory-related disorders?
  a. What are the harms of these interventions?
  b. Do these benefits/harms vary by type of intervention, health condition, or patient functional status, or across outcomes?

We anticipated that this review will be of interest to clinicians, researchers, and policy makers. Our intention was to review the evidence on interventions that could potentially provide a benefit or clearly provide no benefit on patient-centered outcomes for those with cancer and memory-related conditions and have organized and then analyzed the review in different ways to meet the needs of stakeholders. The evidence is first divided by condition (cancer and memory-related disorders). Within each condition, our two key questions, based on type of trial and comparators (efficacy trials in Key Question #1 and comparative effectiveness in Key Question #2), are reviewed. Within each key question, we summarize the effects on each identified outcome across all interventions, and then the effects of trials in each intervention category (e.g., telephone and web-based counseling, couple counseling, etc.) on each outcome. In our summaries, we take into consideration disease stage and the relationship of the patient to the family member in order to determine if specific groups or sub-groups benefit from the intervention.