# EVIDENCE TABLES

Table 1 Cancer Studies – Study Characteristics

Table 2 Cancer Studies – Quality of Life – Physical Functioning

Table 3 Cancer Studies – Quality of Life – General Psychological Functioning

Table 4 Cancer Studies – Quality of Life – Social Functioning

Table 5 Cancer Studies – Quality of Life – Global Quality of Life

Table 6 Cancer Studies – Depression and Anxiety

Table 7 Cancer Studies – Symptom Control/Management

Table 8 Cancer Studies – Relationship Adjustment

Table 9 Memory-Related Disorders – Study Characteristics

Table 10 Memory-Related Disorders – Physical Functioning

Table 11 Memory-Related Disorders – Cognitive Function

Table 12 Memory-Related Disorders – Quality of Life – Global Functioning

Table 13 Memory-Related Disorders – Symptom Management/Control

Table 14 Memory-Related Disorders – Patient Depression/Anxiety

Table 15 Memory-Related Disorders – Hospitalization or Institutionalization