# PEER REVIEW COMMENTS/AUTHOR RESPONSES

REVIEWER COMMENT | RESPONSE
1. Are the objectives, scope, and methods for this review clearly described?
Yes. This is a well-done systematic review. | Thank you.
In general, yes. Although I was confused by the term alternative family oriented intervention in KQ2 and remained so during my reading. | Our intention in Key Question #2 was to evaluate the comparative effectiveness of interventions. Typically one family–involved intervention was the primary intervention and it was compared to an alternative intervention. For example, one trial compared a skill building and problem solving intervention to an intervention where families received supportive telephone calls. The alternative family condition was the group receiving the phone calls. We have revised the wording throughout the report to better reflect this description.
Yes | No response needed
Yes | No response needed
Yes. The objectives, scope, and methods are clearly described in significant detail ensuring that the reader is aware of the implications as well as the limitations of the review. | Thank you.
Yes. I’m not quite sure why it was appropriate to exclude non-U.S. studies. A supporting citation would be useful for the strength of evidence ratings. | We have added a reference to the strength of evidence tables in Executive Summary and report.
No.; 1. It is unclear how the ‘quality’ of studies was determined; no reference was included. I am particularly concerned about the lack of consideration given to power (studies that were adequately powered to detect differences in the primary outcome should be rated highly) and the over consideration given to blinding (most behavioral interventions cannot be blinded to the subject or the interventionalist – it’s just not feasible- the only place where blinding is possible is at the level of analysis).; 2. I believe that it is not appropriate to extract data on any outcomes that the study was not originally designed to affect or powered to detect. I would prefer an approach where no primary outcomes of interest were chosen by the authors of the synthesis; the synthesis team would simply judge the quality of each study and list each study’s primary outcomes as they were originally published. An alternative approach would be to examine results by outcome including only RCTs that were powered to detect that outcome (e.g. Table 2 Cancer Studies – Quality of Life – Physical Functioning would only include those studies that had physical function as an outcome of interest, rather than including those who had physical function as a possible modifier or confounder).; 3. Your search strategy did not include the words “caregiver” or “carer”. Not sure this would make a difference, but those terms have been used successfully in other reviews.; 4. A large number of studies were excluded because “intervention is not counseling, therapy, education, or family based treatment involving a family member.” How many were excluded because of the modality of the intervention and how many were excluded because they did not involve a family member?; 5. I do not believe it is fair to say that “evidence does not favor family-involved interventions over …” but rather “there is insufficient evidence to say that family involved interventions improve x,y,z outcomes”. If you judge that most of the studies you examined were methodologically weak, then you need to temper the strength of the conclusions you can make. | 1. We have revised the description of the method we use for assessing risk of bias and quality. We base these assessments on approaches used by the Cochrane Collaboration and AHRQ-EPC (Higgins, et al, 2001; Owens, et al 2010). Risk of bias assessments do not include power/sample size as quality measures (though this would be incorporated into the strength of evidence we have included). Power is more likely to affect the precision of the estimate rather than bias results and alter study quality (we could have a high quality small study and a poor quality large study). We agree that blinding is difficult, though the subjects and assessors could be blinded to the study objective, and outcome assessors, when used, could be blinded to the randomized condition. Risk of bias is most concerning in these situations where outcomes are subjective. Our findings did not change materially when focusing on studies of low risk of bias (good to fair quality studies).; 2. We respectively disagree. While the reviewer’s approach certainly would be sound for choosing an intervention for a specific patient, our approach is consistent with standard systematic review methodology and guidance statements used by AHRQ- EPC and Cochrane.; 3. We used two databases for our search: PsycInfo and MEDLINE. Our search strategy for PsycInfo did include the word caregiver. For MEDLINE, however, you are correct, we did not include “caregiver” as a MeSH term in our final search. The definition (in MEDLINE) includes trained medical, nursing, and other health professionals as well as family, teachers, clergy, social workers, and fellow patients. In our work to refine the search terms, we found that many of the articles captured when searching with the term caregiver included formal, paid caregivers. Therefore, we first used the terms family and couples. We then also used the term “home nursing.” Home nursing focused more on non-professional care.; 4. We did not identify how many studies were uniquely excluded for each specific reason. The exclusion typically was for the full phraseology not separated items. Therefore, studies may have met multiple exclusion criteria (e.g., conducted outside the US and included teachers, instead of family members). Each specific reason was not recorded; instead, if any of the exclusion criteria were met, the study was excluded.; 5. We have reviewed and revised this statement to include that there is insufficient evidence for outcomes. However, we revised this statement because the heterogeneity of the studies makes it difficult to be unequivocal. We retain our statement that positive effects were infrequent, not consistently seen, typically small in magnitude, often based on multiple outcome reporting or subscale findings. Thus any positive effects and the clinical importance of these findings should be viewed with caution.
2. Is there any indication of bias in our synthesis of the evidence?
No. Although there were few studies that were of “good” quality, at times I felt there was not enough attention to weighting these studies more than those of poorer quality. This concern was somewhat lessened given that only RCTs were included | Because we did not conduct a meta-analyses we could not formally weight studies. We do note, however, that only 2 of 26 cancer trials were rated good quality. For memory trials, six trials were rated good quality. Five of the 6 reported one significant intervention effect each. However, these effects were across 3 different outcomes. Limiting our evaluation to just good quality studies did not change the strength of evidence.
No | No response needed
No | No response needed
No | No response needed
No. There is no evidence of bias in the review. | No response needed
No. I do wonder about the precision of the comparisons, in the sense that it’s pretty hard to know the quality of the family-oriented interventions reflected in these studies. They also are likely to vary quite a bit in the degree to which they include family members vs. involve family members, etc. In other words, systemic interventions vary a lot and that makes this review challenging. The general vs. specific focus the authors identify is helpful and should be pursued. Perhaps the authors could give some specific examples when they make this point so readers have even greater clarity | Thank you. We have incorporated this suggestion into the discussion.
Yes.; 1. By extracting data on outcomes that the studies were not powered to detect, the synthesis is systematically biasing towards finding no effect. I believe your conclusions would be very different if you examined only the outcomes originally chosen as the primary outcomes for each study.; 2. Also, if the authors of the synthesis examined only data that was unadjusted, this would also bias the results of the synthesis towards finding no effect. One major challenge in caregiver interventions is sample size – recruitment of dyads is difficult and, thus, studies typically have small samples. With a smaller sample size, the chances are higher that the intervention and control groups have differences at baseline that need adjusting in the final analysis. Thus, unadjusted data is often not reported in caregiving studies (as you saw) – and, when it is reported, should NOT be used to base conclusions upon. | We agree that recruitment to these studies is difficult and that future, large and methodologically rigorous randomized trials are needed. We do, however, respectfully disagree about our decisions on data extraction and study inclusion. We conducted the systematic review based on standard and validated methodology established by the AHRQ Evidence-based practice centers. We commented on the size, quality, applicability of studies and consistency of findings. Not including smaller studies or studies not powered for certain outcomes would systematically eliminate findings from many studies and result in a small study publication bias that would artificially increase effect size. We have commented on findings where adjusted results were provided throughout the report. Small studies, while potentially resulting in “imbalance,” are unlikely to result in systematic bias-the purpose that randomization is intended to avoid.
3. Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked?
Yes. The effect of telephone support groups on costs of care for veterans with dementia. Wray LO, Shulan MD, Toseland RW, Freeman KE, Vásquez BE, Gao J. Gerontologist. 2010 Oct;50(5):623–31. Epub 2010 May 27. | Thank you for the reference information. We have added this study to the review
Maybe. I wondered why you didn’t include the REACH II study, which used RMBPC as one of its outcome measures – it is included as part of the multicomponent outcome. | Thank you for the suggested references. We have reviewed the two papers.
1. Coon, David, W., et al. (2004). Ethnicity and time to institutionalization of dementia patients: A comparison of latina and caucasian female family caregivers. Journal of American Geriatrics Society, 52, 1077–1084. | Coon (Mausbach 2004) reported results by ethnicity but not by intervention group so the study did not address our key questions.
2. REACH II Investigators (alphabetical order: Belle, S.H., Burgio, L., Burns, R., Coon, D., Czaja, S., Gallagher-Thompson, D., Gitlin, L., Klinger, J., Koepke, K. M., Lee, C. C., Martindale-Adams, J., Nichols, L., Schulz, R., Stahl, S., Stevens, A., Winter, L. & Zhang, S.) (2006). Enhancing the quality of life of dementia caregivers from different ethnic or racial groups: A randomized, controlled trial. Annals of Internal Medicine, 145, 727–738. | Belle et al. 2006 has been added to the review.
No | No response needed
Yes Good selection of articles. Other potential articles:; 1. Belle, SH et al. (2006). Ann Intern Med 2006, Nov 21;145(10): 727–38 (includes institutionalization of dementia patients as an outcome of a caregiver RCT; 2. Linda Nichols’ research with the REACH program (although I could not easily find articles in PubMed related to her intervention with dementia caregivers – I think she has unpublished results); 3. 2012 articles:; a. Failho, PP et al. (2012) Arq Neuropsiquiatr. October 70(10) 786–790; b. Liddle, J et al Int Psychogeriatr Dec 24 (12) 1927–42 | Thank you for the suggested references. We have reviewed the three suggested papers: We have added Belle 2006 to the review. We identified another reference from the REACH study (Burns 2003) and have added that paper to the review. Failho did not meet our criteria; it was conducted in Brazil. Liddle did not meet our criteria; it was conducted in Australia.
No. I am not aware of any published or unpublished studies that were overlooked. | No response needed
I’m not aware of any. | No response needed
No | No response needed
4. Please write any additional suggestions or comments below. If applicable, please indicate the page and line numbers from the draft report.
1. Executive Summary – Terms are not defined before they are mentioned in the ES – is that function assumed to be managed by the glossary of terms at the end of the ES?; 2. I remained confused about the definition of alternative family oriented interventions.; 3. The criteria for good, fair and poor quality of studies are not explicitly defined until (the first place I could find) page 72 (but I did not read the Cancer section).; 4. page 4, - paragraph 1 under KQ1, last sentence is confusing; 5. page 7, paragraph 3, bullet 2, are weekly nurse telephone calls counseling?; 6. Tables. Several comments about tables. I could not find definitions for risk of bias, directness, precision, consistency or evidence rating in the text. Some of them are later, after the tables have been presented for example strength of evidence rating is on page 32; others I could not find it all. Also table information is not consistent, for example, sometimes there is in and between entries under risk of bias sometimes a semicolon, sometimes commas are used sometimes not. This type of sentence is often under precision: Three trials reported (one good, one far, one poor)… I believe that the parenthetical expression should modify trials and not reported as in: Three trials (one good, one far, one poor) reported; 7. the word veteran is not always capitalized.; 8. Figure 1 is presented before it is referenced in the text/; 9. Page 30, paragraph 1. Text says articles were conducted in the US. this sentence needs to be clarified.; 10. Page 30/31, last paragraph area in general psychological function does not correspond with mental health conditions in the DSM; where does this leave depression and anxiety which are secondary outcomes.; 11. I know you will fix all this later on-multiple references within parentheses are not organized. some references are not found or are mislabeled-Gitlin has a 2010 a and a2010 ACT; Mittleman is sometimes done as 2004/2006.; 12. Page 66, paragraphs 3 and 5. I am not exactly sure how these two paragraphs are different. Also, paragraph 2 talks about family focused CBT interventions while talks about multicomponent intervention targeted at family members. In the first instance the CBT appears to be the most important, in the second instance the multicomponent. This is also the case on page 76 where the heading is family focused CBT interventions, not multicomponent.; 13. page 67, paragraph 2. Support groups for patients with early-stage memory loss does not indicate that there is a family component; 14. The formatting changes somewhere in the text and the headings are smaller.; 15. Page 82. Paragraph 4, first sentence is confusing.; 16. Page 88 – paragraph 3. None were superior to alternative interventions (such as? – ones that they have listed in their studies?) Also, last sentence is unclear – where were there no data?; 17. Page 93, paragraph 1 (and in conclusion of Executive Summary). Needs to read: In this review we assess the evidence of family-involved interventions for improving outcomes of adult patients with cancer and memory-related conditions.; Next sentence is a bit unclear. Does individually-focused mean patient focused? And interventions that provide only health or psychoeducation? Not sure what the health means in this – health education? | 1. We have corrected this-terms are now defined.; 2. Please see explanation in first comment.; 3. We have clarified the definitions of good, fair, and poor quality studies in the Methods and Results sections of the Executive Summary and full report.; 4. Thank you. We have revised this sentence.; 5. We have clarified this statement by clarifying that nurse phone calls were to manage uncertainty and patient concerns.; 6. We have added these definitions to the text and corrected the inconsistency in reporting; we agree with your comment about placement of the parenthetical expressions.; 7. We have corrected this throughout.; 8. We have corrected the reference to Figure 1.; 9. We have clarified this sentence.; 10. General psychological functioning is grouped under quality of life and corresponds to psychological functioning. This is in contrast to more specific mental health conditions, such as depression and anxiety, which are in the DSM. In order to avoid any confusion about this, we have removed the classification of primary and secondary outcomes.; 11. We have changed the references to superscripts and clarified the multiple reference citations.; 12. We agree this was not clear and have made changes to clarify the differences across the types of interventions.; 13. We have clarified this statement.; 14. We have reviewed the formatting and font size and made changes as needed.; 15. We have revised this sentence.; 16. We have revised these sentences.; 17. We have revised these sentences to indicate patient-focused instead of individually-focused and health education and psychoeducation, instead of health and psychoeducation.
While we understand the rationale for limiting results to patient outcomes, we question the wisdom of this with regard to dementia and memory impairment. We think that preventing caregiver burnout is a critical issue that has major implications for the well-being of the person with the disease. The data on caregiver interventions thus far do not indicate they reduce out-of-home placements, but these are likely overdetermined by many other factors—number of available caregivers, finances, health of the caregiver, kinds of care facilities available, etc. However, it is certainly plausible that caregivers who feel more supported and educated can adhere better to patient treatment plans, provide better care, etc. With regard to aging related memory disorders, having a psychosocial intervention goal of improving patient behavior seems unlikely at this point. | The topic nominated for this review was to examine the effect of caregiver interventions on patient outcomes. We agree that caregiver burnout is a critical issue and that by limiting the review to only patient outcomes, we are not able to present evidence on the potential pathways by which caregiver experiences affect patient outcomes. We do acknowledge this as a limitation in the discussion and recommend this as a potential area for further research. We should note that there have been recent VA reviews on caregiver interventions to improve caregiver outcomes, such as managing problem behavior (Goy, et al, 2010; Kansagara, 2012), but, as we describe in the background section for the report, few reviews have extended beyond the caregivers to examine the effects of these interventions on the patient.
Well written and comprehensive | Thank you.
The review is very thorough and certainly thought provoking in light of VA’s focus on supporting family members and Caregivers. Most studies focus on family/caregiver outcomes and not patient outcomes. It will be essential to establish a balance of these two outcomes in order to provide the best programming. | Thank you. We agree with the need to consider family/caregiver and patient outcomes in making program decisions.
I don’t know what style guide is being used – text citations don’t appear to be listed by author or year. p. 83 – Font size shifts p. 94 – I find the second sentence in the paragraph beginning ‘based on our findings’ hard to follow. p. 96 – is an author name missing for the first citation in the reference list? | Thank you. We have addressed these concerns.
Personally, I prefer using the term “informal caregiver” rather than “family” (especially if you are including friends as possible subjects). | We agree that in many cases, caregiver is the appropriate term. However, in others, where more emphasis is on psychosocial adjustment to the disease or treatment, it may be less appropriate.
5. Are there any clinical performance measures, programs, quality improvement measures, patient care services, or conferences that will be directly affected by this report? If so, please provide detail.
Caregiver Support Services and GEC would be interested. There is a caregiver conference call led by John Piette, PhD that would be interested. There have been a couple of VHA Caregiver conferences largely organized by Caregiver support Services. | Thank you for this suggestion.
Not that I know | No response needed
Conferences for geriatric clinicians, such as AGS and GSA would be appropriate | Thank you for this suggestion.
The Caregiver Support Program Office as well as the Office of Mental Health will be impacted by this review as they continue to roll out legislatively mandated programs to support families and Caregivers. In addition, there is much interest in Congress, Veteran Service Organizations, Non Governmental Organizations, Veterans and their families and Caregivers as well as other stakeholders to provide support and assistance to families, especially of those ill and injured. VA will need to evaluate the impact that such programs have, both on family members or Caregivers, as well as the impact on Veterans in order to proceed with such programming. | Thank you for this suggestion.
I’m sorry, but I’m not sufficiently familiar with the VA to be able to say | No response needed
The VA’s national caregiver program may be affected by this report; funding for expanding programs to help caregivers provide better care for cancer and dementia patients may be affected if there is a sense that research shows no benefit to such interventions. Similarly, VA HSRD may choose to reduce the funding it provides to caregiving research if the impression is given that studies show no benefit. | We thank the reviewer for these comments and appreciate that our report has implications for health care practice, policy and research. Our goal is to objectively identify and synthesize the existing evidence and provide an assessment of the effectiveness and harms of interventions. We do not set policy, make practice implementation or research funding decisions. These may be made by factors beyond the available evidence, though we hope our report provides evidence based guidance in these decisions. We have reviewed our discussion and summary recommendations to make these issues clear. We believe that this report provides strong support that future research is needed particularly assessing the effect of currently rolled out VA programs and any future design and implementation of caregiver programs. We also believe that this report may help reduce implementation of ineffective and costly programs and target interventions of established effectiveness.
6. Please provide any recommendations on how this report can be revised to more directly address or assist implementation needs.
It would be useful to draft 1–2 RFPs for VA R&D to address gaps in literature that are nicely outlined in review. | Thank you for this suggestion.
Do you have any recommendations on what we should be doing clinically? | We have added to the discussion how clinicians might use this report. Because the evidence does not strongly favor one intervention over another, it is difficult to make recommendations on how our findings can directly affect practice.
We think these negative results, especially regarding aging related memory disorders, may have implications for the VA Social Work and Care Management Program Office as they consider their program goals | No response needed
The authors conclude that the previous interventions have had no or modest effects on patient outcomes, thus implementation most of the interventions would not be helpful. However, it is commendable that the authors provide recommendations for improving research in this area and emphasize that interventions, which target specific areas (sleep, etc.) are most effective. | Thank you.
No additional comments | No response needed
My main uncertainty is whether sufficient attention was paid to the quality of the family interventions in the studies examined. I notice fairly frequently that the sophistication of measurement about families is low – could the same be true of the quality of the family- focused intervention strategy? | Throughout this revised report, we call attention to the quality of the family interventions, and we agree that not all studies are methodologically rigorous. We have also added our criteria for assessing quality to the executive summary. One recommendation in the discussion is for more methodologically sound research to be developed, using measures that are validated, comparable, and reporting findings at consistent intervals.
For the reasons stated in #5, I would strongly recommend that the summary and discussion state that the science is limited and, while there is insufficient evidence to say that caregiver interventions improve patient outcomes, there have been some promising findings in the areas of x, y, z… | As noted above, our goal was to identify, synthesize and communicate the evidence on the key questions. We have, however, reviewed and revised our discussion section. While we conclude that there is low to moderate strength of evidence that family directed caregiver interventions are not more effective than usual care or other patient- or family- directed interventions for improving patient outcomes, we have revised the conclusions to point to areas that have insufficient evidence and where additional, methodologically rigorous research is needed.