# SEARCH STRATEGIES

Database: Ovid MEDLINE(R)

Search Strategy:

1. exp family/
2. couples.mp.
3. exp home nursing/
4. (grandparent: or grandmother: or grandfather:).mp.
5. exp legal guardians/
6. or/1–5
7. couples therapy/ or family therapy/ or marital therapy/ (8466)
8. 6 or 7
9. exp Infertility/ or exp Infertility, Male/ or exp Infertility, Female/ or exp Fertilization in Vitro/ or exp Reproductive Techniques, Assisted/ or exp Insemination, Artificial/
10. 8 not 9
11. limit 10 to (English language and yr=”1980 -Current”)
12. limit 11 to (“newborn infant (birth to 1 month)” or “infant (1 to 23 months)” or “preschool child (2 to 5 years)” or “child (6 to 12 years)”)
13. 11 not 12
14. limit 13 to meta analysis
15. (systematic adj review:).mp.
16. 13 and 15
17. 14 or 16
18. limit 13 to randomized controlled trial

Database: PsycINFO

Search Strategy:

1. exp family/ or exp family members/ or exp spouses/ or exp couples/
2. exp caregivers/ or exp stepparents/ or exp siblings/ or caretaker:.mp.
3. exp grandparents/ or legal guardian:.mp.
4. or/1–3
5. couples therapy/ or family therapy/ or marital therapy/
6. 4 or 5
7. exp Infertility/ or exp Reproductive Technology/
8. 6 not 7
9. limit 8 to (English language and yr=”1980 -Current”)
10. limit 9 to 100 childhood <birth to age 12 yrs>
11. 9 not 10
12. meta analysis/ or (systematic adj review:).mp.
13. 11 and 12
14. (randomized or rct).mp.
15. 11 and 14