# SUMMARY AND DISCUSSION

We reviewed the literature examining the benefits of cannabis in chronic pain and PTSD populations, as well as literature examining potential harms relevant to these populations. Table 10 summarizes the evidence on the benefits and harms of cannabis use. Overall, we found limited evidence on the potential benefits and harms of cannabis use in chronic pain populations. We found low-strength evidence that cannabis preparations with precisely defined THC-cannabidiol content (most in a 1:1 to 2:1 ratio) may alleviate neuropathic pain but insufficient evidence in populations with other types of pain. The applicability of these findings to current practice may be low, in part because the formulations studied may not be reflective of what most patients are using, and because the consistency and accuracy of labeled content in dispensaries are uncertain.^125^ Furthermore, most studies are small, many have methodological flaws, and the long-term effects are unclear given the brief follow-up of most studies. There is insufficient evidence of effects on quality of life or functional status.

Table 10 Summary of Evidence for the Benefits and Harms of Cannabis in Chronic Pain or PTSD Populations

| N studies | Findings | Strength of Evidence^a^ | Comments
Chronic Pain
- Multiple sclerosis (MS) | 4 Low ROB studies (combined N=1017; 24 to 424 per study):; - 2 of THC/CBD capsules; - 1 of nabiximols; - 1 of sublingual spray delivering THC, CBD, or THC/CBD combined; 3 Unclear ROB studies of nabiximols (combined N=562; 36 to 337 per study) 7 High ROB studies (combined N=430; 13 to 160 per study):; - 3 of nabiximols; - 2 of THC/CBD capsules; - 1 of smoked THC; - 1 of oral THC | Favorable effect on pain and spasticity: Significant relief from patient-reported muscle stiffness, pain, and spasticity occurred with 12 to 15 weeks of treatment with THC (2.5 mg)/CBD (1.25 mg) capsules in 2 studies. A 12-week study of nabiximols (2.7 mg THC/2.5 mg CBD oromucosal spray) reported significant improvement in spasticity. A sublingual spray delivering 2.5 mg of CBD, THC, or both for sequential 2-week periods reported mixed effects. THC alone significantly improved pain and spasticity, but CBD alone and THC/CBD combined had inconsistent effects. | Low | Few methodologically rigorous studies, but fair number of patients; inconsistent results; little long-term data; restrictive entry criteria in largest study which only included patients with initial response in run-in phase; applicability to formulations available in dispensaries may be low
- Multiple sclerosis (MS)
- Multiple sclerosis (MS) | 4 Low ROB studies (combined N=1017; 24 to 424 per study):; - 2 of THC/CBD capsules; - 1 of nabiximols; - 1 of sublingual spray delivering THC, CBD, or THC/CBD combined | Other outcomes: Small improvements in sleep in 4 studies: Self-reported sleep quality improved in 2 studies of THC/CBD capsules. Nabiximols were significantly superior to placebo for reducing sleep disruption in a 12-week study (N=241). Sleep improved significantly in a small study (N=24) of a sublingual spray containing 2.5 mg each of CBD:THC. | Low (sleep) | Few methodologically rigorous studies, but fair number of patients; inconsistent results; little long-term data; restrictive entry criteria in largest study which only included patients with initial response in run-in phase; applicability to current practice may be low
- Multiple sclerosis (MS) | 4 Low ROB studies (combined N=1017; 24 to 424 per study):; - 2 of THC/CBD capsules; - 1 of nabiximols; - 1 of sublingual spray delivering THC, CBD, or THC/CBD combined | Other: Nabiximols were significantly superior to placebo for Barthel Activities of Daily Living (P=.0067), Physician Global Impression of Change (P=.005), Subject Global Impression of Change (P=.023), and Carer Global Impression of Change (P=.005) in Function in a 12-week study (N=241). | Insufficient (other outcomes) | Only one study of nabiximols – not tested otherwise
- Neuropathic pain | 11 low ROB studies (combined N = 593); - 4 of smoked THC (combined N = 150); - 3 of vaporized THC (combined N = 97); - 3 of nabiximols (combined N = 312); - 1 of oromucosal spray delivering THC or THC+CBD (N = 34); 1 unclear ROB study of nabiximols (N = 30) 1 high ROB trial (N = 125) | Studies did not find a clinically significant between-group difference on continuous pain scales, but a higher proportion of intervention patients had clinically significant pain relief up to several months later. In a meta-analysis of 9 studies, intervention patients were more likely to report ≥30% improvement in pain (combined RR, 1.43 [95% CI, 1.16-1.88]; I^2^ = 38.6%; P = 0.111). | Low | Few patients enrolled in most low ROB studies; inconsistent results; marked differences among studies in dosing and delivery mechanism; brevity of study duration; low applicability to formulations available in dispensaries.
- Neuropathic pain
- Neuropathic pain | 1 Low ROB study of smoked THC (N=23) | Other outcomes reported in low ROB studies: A study of vaporized cannabis reported that 25 mg with 9.4% THC administered as a single smoked inhalation 3 times daily resulted in significant improvements in sleep quality. | Insufficient | Only one small study
- General/other/mixed populations | 2 Low ROB studies:; - 1 trial of sublingual spray delivering THC, CBD, or THC/CBD combined (N=34); - 1 observational study of cannabis containing 12.5% THC (smoked, oral, or vaporized) (N=431); 3 Unclear ROB studies of nabiximols (combined N=428; 10 to 360 per study) 3 High ROB studies (combined N=265; 18 to 177 per study):; - 2 of nabiximols; - 1 of THC capsules | Small improvements in pain, but no effect on sleep, mood, quality of life. | Insufficient | Only one small low ROB study in which the bulk of the patients had MS; larger observational study had high drop-out rate
PTSD | 2 observational studies in Veterans with PTSD:; - 1 Medium ROB (N=2276); - 1 High ROB (N=700) | Cannabis was not associated with an improvement in mental health symptoms. | Insufficient | No trials; only 2 observational studies with methodologic flaws
Harms
- General AEs | 2 systematic reviews of chronic pain | Cannabis-based treatments were associated with an overall higher risk of short-term, non-serious AEs. | --- | Consistent findings except for serious AE
- Medical harms; ➢ Pulmonary function | 2 Low ROB prospective cohort studies with 20-32 years follow-up (combined N=6053) 1 systematic review of 5 observational studies (3 cohort, 2 cross-sectional) (combined N=851) | In young adults, low levels of cannabis smoking did not adversely affect lung function over about 20 years. A previous meta-analysis of 5 studies found no increased risk for pulmonary adverse effects, OR (95% CI): 0.80 (0.46-1.39). | Young adults: Moderate Older adults: No evidence | Two well-done prospective cohort studies, but limited information about effects of heavy use and no information in older or multimorbid populations
➢ Cardiovascular | 2 High ROB observational studies:; - 1 case-crossover (N=3882); - 1 cohort study (N=2097) | Cannabis use at the time of myocardial infarction was not associated with mortality after mean 12.7 years follow-up, but longitudinal use was not assessed. Risk of myocardial infarction within an hour of cannabis use was significantly elevated compared with periods of non-use but this finding may be inflated by recall bias, OR (95% CI): 4.8 (2.9-9.5). | Insufficient | Recall bias; inadequate controlling for confounders; lack of longitudinal exposure data
➢ Cancer; ▪ Lung | 1 patient-level meta-analysis of 6 case-control studies (2150 cases) 1 High ROB cohort study (N=49,231) | The meta-analysis found no association between light cannabis use and lung cancer. | Low | Recall bias; mostly light users, few heavy users; the large cohort study had no information about exposure over time
▪ Head/neck/oral | Meta-analysis of 9 case-control studies (5732 cases) | No association between cannabis use and cancer, OR (95% CI): 1.02 (0.91-1.14); generally consistent across studies and no evidence of dose-response. | Low | Imprecise exposure measurement with potential recall bias; ever use among studies ranged from 1 to 83%
▪ Testicular | Meta-analysis of 3 High ROB case-control studies (719 cases) | An increase in cancer risk for weekly users compared to never-users appeared with non-seminoma cancers but not seminoma cancers, OR (95% CI): 1.92 (1.35-2.72). | Insufficient | Potential confounding from recall bias and tobacco use
▪ Transitional cell | 1 High ROB VA case-control study (52 cases) | Risk of cancer with > 40 joint-years cannabis use compared to none, OR 3.4 (unadjusted, P=.012). | Insufficient | One very small case-control study with several methodologic flaws
➢ Motor vehicle accidents | Meta-analysis of 21 observational studies (combined N=239,739) | Increase in collision risk, OR (95% CI): 1.35 (1.15-1.61). | Moderate | The small but significant increase in risk was seen consistently across numerous sensitivity analyses and after adjustment in meta-regression analyses
- Mental health; ➢ Suicidal behaviors | No studies in chronic pain or PTSD populations. | --- | No evidence (chronic pain or PTSD) | Meta-analysis of 4 studies in the general population reported significantly increased odds of suicide with any cannabis use, OR (95% CI): 2.56 (1.25-5.27).
➢ Mania | No studies in chronic pain or PTSD populations | --- | No evidence (chronic pain or PTSD) | A systematic review found an increased incidence of new-onset mania symptoms among populations without a diagnosis of bipolar disorder, OR (95% CI): 2.97 (1.80 to 4.90).
➢ Psychosis | 1 systematic review 7 studies including patients without psychotic symptoms at baseline:; - 3 Low ROB studies; - 3 Medium ROB studies; - 1 High ROB study | History of cannabis use was associated with an increase in risk of developing psychotic symptoms. | Low | Consistent evidence from large observational studies and some evidence of increased risk with higher levels of use; consistent with data from small experimental studies suggesting risk of acute psychosis in some patients; magnitude of risk unclear and not specifically studied in chronic pain or PTSD populations
➢ Cognitive effects | 1 systematic review of 33 studies | Active long-term cannabis use associated with small negative effects on all aspects of cognition. Mixed, inconsistent findings on long-term effects in past users. | Moderate Insufficient (past use) | Consistent data from large number of studies on effects on active long-term use, but inconsistent findings from smaller number of studies regarding effects in those that were abstinent and no data available specifically in chronic pain or PTSD populations
➢ CUD | One large cohort study (N=34,653; N = 1279 past year cannabis use in last year) | OR incident CUD 9.5 (95% CI 6.4-14.1) Prevalence CUD (among those using in last year) 36% Prevalence past year cannabis dependence 7.7% Prevalence past year cannabis abuse 28% | Low | In cross-sectional studies, the prevalence of CUD in chronic pain populations was about 2%

Abbreviations: AE = adverse event; CBD = cannabidiol; CI = confidence interval; CUD = cannabis use disorder; MS = multiple sclerosis; N = number; OR = odds ratio; PTSD = post-traumatic stress disorder; ROB = risk of bias; THC = tetrahydrocannabinol; VA = Department of Veterans Affairs.

a The overall quality of evidence for each outcome is based on the consistency, coherence, and applicability of the body of evidence, as well as the internal validity of individual studies. The strength of evidence is classified as follows:

- High = Further research is very unlikely to change our confidence on the estimate of effect.
- Moderate = Further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate.
- Low = Further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.
- Insufficient = Any estimate of effect is very uncertain.

Among neuropathic pain studies, we found a discrepancy between continuous and dichotomous pain outcomes. Possible interpretations are that cannabis is simply not consistently effective or that, although cannabis may not have clinically important effects on average, subgroups of patients may experience large effects. We did not find data to clarify which subgroups of patients are more or less likely to benefit.

We found no trials examining the effects of cannabis in PTSD populations, and there was insufficient evidence from observational studies to draw conclusions about its effectiveness in patients with PTSD.

Even though we did not find strong evidence of benefit for most indications, clinicians will still need to counsel patients with chronic pain or PTSD who are using or requesting to use cannabis for therapeutic or recreational purposes. Therefore, understanding what is known and not known about potential harms of cannabis is also important.

There is moderate-strength evidence that at least light to moderate cannabis smoking does not adversely impact lung function over about 20 years. However, there is no evidence examining the effects in older patients, or those with multiple medical comorbidities. Moreover, the limited evidence examining the effects of heavy use (the equivalent of one joint daily for 7 years or more) suggests a possible deleterious effect on lung function over time.

There is low-strength evidence that light to moderate cannabis use is not associated with lung cancer or head and neck cancer diagnoses independent of tobacco use, but the data are limited to case-control studies and do not address heavy use. However, there is at least biologic plausibility that cannabis smoking has the potential to increase the risk of lung cancer based on data showing that cannabis use is associated with macrophage dysfunction, tar deposition, and cytologic abnormalities.^126^ There is insufficient evidence about effects on other cancers.

While there is a biologically plausible link between cannabis use and cardiovascular risk given data showing adverse effects on hemodynamic parameters and anginal threshold,^73^ we found insufficient evidence examining whether cannabis use is associated with cardiovascular events over the long-term.

There are potentially serious mental health and adverse cognitive effects of cannabis, though there is not enough data to characterize the magnitude of risk or in whom the risk is highest. Cannabis appears to be associated with at least small, short-term deleterious effects on cognition in active users, but long-term effects in past users are uncertain. We found no data on the risk of mania or suicidality in chronic pain or PTSD populations specifically, but cannabis has been associated with these risks in other populations.

We found stronger data suggesting an association between cannabis use and the development of psychotic symptoms over the long-term and limited data suggesting a risk of acute psychosis immediately following cannabis use. There is no data to directly assess whether the risk of psychotic symptoms is related specifically to the THC content of the formulation used, but this is biologically plausible, there are case reports of severe acute psychosis after ingestion of edibles with very high THC concentrations,^123^ and CBD may in fact have antipsychotic effects.^127,128^

Intuitively, patients with PTSD or patients with serious mental illness, especially those already suffering with hypervigilance, agitation, and anger management issues, might be at higher risk of suffering serious consequences should they experience any adverse effects, especially psychotic symptoms. Observational studies in PTSD populations suggest a signal for harm, though the studies are inconclusive.^60,61^ While clinicians do not have adequate data to quantify risks and benefits for PTSD patients, they might consider discussing potentially serious mental health adverse effects during shared decision-making discussions. They also might consider discussing other evidence-based interventions recommended by the 2010 VA/Department of Defense (DoD) Clinical Practice Guideline for PTSD.^129^ Specifically, “A” level interventions with “strong recommendations” for use include selective serotonin reuptake inhibitors (SSRIs), selective norepinephrine reuptake inhibitors (SNRIs), and “trauma-focused psychotherapy that includes components of exposure and/or cognitive restructuring, or stress inoculation training.” Similar recommendations based on research synthesized through 2013 were made by the Institute of Medicine (IOM).^130^ This IOM report noted, “A 2013 meta-analysis of treatment efficacy for PTSD was consistent with the VA/DoD guideline in finding that cognitive therapy including cognitive processing therapy (CPT); exposure therapy, such as prolonged exposure (PE) therapy; and eye movement desensitization and reprocessing (EMDR) were effective psychotherapies, and SSRIs were the most effective pharmacotherapies.”

Finally, there are a number of adverse effects that appear to be related to cannabis use and may be important for clinicians to be familiar with, but whose incidence has not been well-characterized. These are reviewed above in the emerging harms section and include infectious disease complications, cannabis hyperemesis syndrome, inadvertent overingestion of THC and associated psychosis related to edible cannabis, and violent behavior.

Currently, the Centers for Disease Control and Prevention recommends the use of evidence-based non-pharmacologic therapy – such as physical therapy, exercise therapy, and psychologic interventions – and non-opioid pharmacologic therapy as the preferred modalities to treat chronic pain.^131^ After trying first-line options, clinicians may continue to struggle with the often difficult treatment of chronic pain in patients who have not responded. Cannabis may be perceived as a safer strategy in these patients.^132^ Indeed, the scale and severity of adverse events, including death, seen with opioids have not been described with cannabis use in the literature (though there is also simply less research available on cannabis than opioids).^132^ However, there are no studies directly comparing cannabis to opioids, and there is no good-quality data examining what impact cannabis use actually has on opioid use and opioid-related adverse effects. We found no observational studies that met inclusion criteria, but a growing body of cross-sectional literature suggests negative opioid-related correlates among individuals who use cannabis and opioids concurrently. These include opioid misuse;^9,10,99,133^ a greater number of opioid refills;^99^ a longer duration of opioid use; a higher dose of opioid medication prescribed;^9^ and endorsement of using opioids and other pain medications without a prescription.^134^ By contrast, one recent open-label study found that pain scores and opioid use decreased over 6 months in a chronic pain population who initiated cannabis treatment, though confidence in the findings is limited by the lack of a control group and the large number of participants lost to follow-up.^135^

## LIMITATIONS

There are a number of limitations to this body of evidence beyond the paucity of well-conducted trials of treatment efficacy. The methodologic issues with each particular trial and observational study are detailed in the quality assessment tables (Appendix C). Applying available data to clinical practice is challenging for several reasons. The data on effectiveness largely comes from studies examining cannabis formulations with known THC and CBD content (most with 1:1 to 2:1 ratio). While dispensaries are increasingly labeling the content of offered products, there are often important discrepancies between labeled and measured content.^125^

While trials were often able to standardize the dosing of the active ingredients in cannabis (THC and CBD), most of the observational studies were not able to characterize the amount of cannabis consumed beyond rough measures such as the average number of joints smoked per day. No observational studies were able to account for the potency of cannabis consumed. In a sense, this lack of precise dosing information reflects the reality of clinical practice and, therefore, the crude approximations of exposure in most studies may still provide useful information. Nevertheless, the evidence base is limited in providing very exact dose-response information beyond the relative distinctions between very heavy and infrequent use. Moreover, the evidence base on harms is limited because there are relatively few patients included in studies with a history of heavy and prolonged cannabis use.

There are also limitations in our approach to synthesizing this literature. Given the broad scope of our review, we relied on existing systematic reviews when available to identify the best available evidence. We believe we are unlikely to have missed important studies both because we only used systematic reviews meeting key quality criteria and because we searched the primary literature for more recent studies not captured by the reviews. As our intention was to provide an overview of evidence that would be important for clinicians to know in counseling patients, we included studies of harms in general populations when we thought it unlikely that the conditions of chronic pain or PTSD would independently contribute to risk (eg, pulmonary or cardiovascular harms when concurrent tobacco use was accounted for). Though we made these determinations through group discussion and in conjunction with a panel of experts, we acknowledge that the choices are inherently subjective to some degree and that there is still the possibility that there are residual confounders relevant to chronic pain or PTSD accounting for observed effects.

## FUTURE RESEARCH

There is virtually no conclusive information about the benefits of cannabis in chronic pain or PTSD populations and limited information on harms, so methodologically strong research in almost any area of inquiry is likely to add to the strength of evidence. Fortunately, it appears that the US government is poised to lift restrictions on access to cannabis for research which should help speed the development of this evidence base which has lagged far behind policy changes regarding the use of cannabis for medical purposes in many states.^136^ Also, there are studies currently being done which should also add to the evidence base in the near future (and are summarized in Key Question 4). Table 9 lists opportunities for future research in each of the areas we reviewed.

Table 9 Suggestions for Future Research

Area of Inquiry | Research Suggestions
Efficacy of cannabis for treating chronic pain | - Populations other than MS or neuropathic pain; - Studies with longer follow-up duration; - Studies with cannabis-naïve patients; - Compare cannabis to other active treatments for pain, including opioids; - Use cannabis preparations that are routinely available to consumers in the US, especially given legalization in more states; - Examine the effects of different THC:CBD ratio preparations, and more study of CBD preparations; - Obtain blood levels of THC and CBD to assess actual level of drug exposure
Efficacy of cannabis for treating PTSD | - RCT of treatment; - Trials comparing to cognitive behavioral therapy, other standard treatments
CUD | - Studies assessing risk of CUD in patients using cannabis
Pulmonary harms | - Observational studies in older and multimorbidity populations
Cardiovascular harms | - Observational studies with more comprehensive information about exposure history
Cancer | - Larger scale observational studies of lung cancer reflecting patterns of use in the US; - More studies to investigate the insufficient evidence of a possible link with testicular and transitional cell cancers
Mental health harms | - Studies on acute psychosis in chronic pain and PTSD populations; - Identification of non-schizophrenic patients at high risk for psychosis; - Risk mitigation strategies for cannabis-induced psychosis; - Studies on mania and suicidality in PTSD populations; - Effects on sleep
Cognitive function | - Studies in chronic pain and PTSD populations
Emerging harms | - Studies characterizing cannabis hyperemesis syndrome in a larger number of patients; - Studies examining treatment and follow-up of patients with cannabis hyperemesis syndrome

## CONCLUSIONS

Although cannabis is increasingly available for medical and recreational use, there is very little methodologically rigorous evidence examining its effects in patients with chronic pain or PTSD. Limited evidence suggests that cannabis may alleviate neuropathic pain, but there is insufficient evidence in other populations. There is insufficient evidence examining the effects of cannabis in PTSD populations. Among general populations, limited evidence suggests that cannabis is associated with an increased risk for potentially serious mental health adverse effects, such as psychosis. Data on its effects on long-term physical health vary; harms in older patients or those with multiple comorbidities have not been studied.