# METHODS

## TOPIC DEVELOPMENT

The research questions for this systematic review were developed after a topic refinement process that included a preliminary review of published peer-reviewed literature, and consultation with internal partners, investigators, and stakeholders. The proposed Key Questions are as follows:

Key Question 1: What are the effects of cannabis on health outcomes and healthcare utilization for adults who have chronic pain?

- Key Question 1A: Do the effects differ by patient subgroup, such as patient medical and mental health comorbidities?

Key Question 2: What are the effects of cannabis on health outcomes and healthcare utilization for adults who have PTSD?

- Key Question 2A: Do the effects differ by patient subgroup, such as patient medical and mental health comorbidities?

Key Question 3: What are the harms associated with cannabis use in adults?

- Key Question 3A: Do the harms differ by patient subgroup, such as patient medical and mental health comorbidities?

Key Question 4: What are important areas of ongoing research and current evidence gaps in research on cannabis for chronic pain or PTSD, and how could they be addressed by future research?

A protocol describing the review plan was posted to a publicly accessible website before the study was initiated.^13^

## SEARCH STRATEGY

Search strategies were developed in consultation with a research librarian. To identify relevant articles, we searched MEDLINE, PubMed, EMBASE, PsycINFO, PILOTS Database, EMB Reviews (CDSR, DARE, HTA, Cochrane CENTRAL, etc), and grey literature sources from database inception through February 2016 (Appendix A). We reviewed the bibliographies of relevant articles and contacted experts to identify additional studies.

To identify in-progress or unpublished studies for Key Question 4, we searched ClinicalTrials.gov, International Clinical Trials Registry Platform (WHO ICTRP), ISRCTN Registry, NIH Reporter, AHRQ Gold, and the American Cancer Society Database of Studies. We also queried the Technical Expert Panel and used snowball sampling techniques to identify relevant ongoing research.

## STUDY SELECTION

The criteria for patient population, intervention, comparator, outcome, timing parameters, and study designs (PICOTS) that apply to each key question are specified in Table 1. We included English-language studies of plant-based cannabis preparations or whole plant extracts such as nabiximols, which is a non-synthetic pharmaceutical product with a standard composition and dose (oromucosal spray delivering 2.7 mg THC/2.5 mg CBD) available only in select European countries. We did not include synthesized, pharmaceutically-prepared cannabinoids such as dronabinol or nabilone because the efficacy of synthetic cannabinoid preparations for chronic pain was examined in 2 recent review articles.^14-16^ However, we broadly defined plant-based cannabis preparations to include any preparation of the cannabis plant itself (eg, cannabis cigarettes, hashish, oils), or cannabis plant extracts. We chose to be broadly inclusive of herbal preparations because US dispensaries offer a wide variety of concentrations and products, and clinicians may encounter patients who have used a variety of preparations.^17^

Table 1 PICOTS and Key Questions

Key Question (KQ) | KQ 1. What are the effects of cannabis on health outcomes and healthcare utilization for adults who have chronic pain? KQ 1A: Do the effects differ by patient subgroup, such as patient medical and mental health comorbidities? | KQ 2. What are the effects of cannabis on health outcomes and healthcare utilization for adults who have PTSD? KQ 2A: Do the effects differ by patient subgroup, such as patient medical and mental health comorbidities? | KQ 3. What are the harms associated with cannabis use in adults? KQ 3A: Do the harms differ by patient subgroup, such as patient medical and mental health comorbidities? | | | KQ 4. What are important areas of ongoing research and current evidence gaps in research on cannabis for chronic pain or PTSD, and how could they be addressed by future research?
Population | Adults with chronic pain | Adults with PTSD | Adults (not otherwise specified) | | | Adults with chronic pain or PTSD
Intervention | Cannabis preparations, including marijuana, hashish, tincture, hashish oil, infusion, and plant extract. [underlined: Exclude]: Synthesized, pharmaceutically prepared cannabinoids (eg, dronabinol, nabilone).
Comparator | Any comparator
Outcomes | ▪ Validated measures of pain intensity and pain-related function (including spasticity); ▪ Validated measures of pain-related outcomes (mood, depression, anxiety); ▪ Validated measures of sleep quality; ▪ Validated measures of quality of life; ▪ Utilization of health services; ▪ Reduction in opioid use or dosage; ▪ Social functioning/disability/employment | ▪ Validated PTSD clinical interviews and symptom inventories, such as: Clinician Administered PTSD Scale (CAPS), PSTD Checklist (PCL), PTSD Symptom Scale (PSS), Posttraumatic Diagnostic Scale (PDS), etc; ▪ Validated measures of mental health symptoms commonly associated with PTSD (mood, depression, anxiety); ▪ Validated measures of sleep quality; ▪ Validated measures of quality of life; ▪ Utilization of health services; ▪ Reduction in benzodiazepine use or dosage; ▪ Social functioning/disability/employment | | Control group required | No control group required (case series accepted) | Not applicable
Outcomes | | | General Population | ▪ Psychotic symptoms (in previously non-psychotic population); ▪ Cardiovascular events; ▪ Pulmonary outcomes (eg, forced expiratory volume [FEV1]); ▪ Infectious disease complications; ▪ Mortality; ▪ Cognitive effects (eg, intelligence quotient [IQ], SLUMS Saint Louis University Mental Status [SLUMS]) | ▪ Fungal infections; ▪ Cannabinoid hyperemesis syndrome; ▪ Other emerging harms | Not applicable
Outcomes | | | Chronic | ▪ Other substance | ▪ CUD | Not applicable
Key Question (KQ) | KQ 1. What are the effects of cannabis on health outcomes and healthcare utilization for adults who have chronic pain? KQ 1A: Do the effects differ by patient subgroup, such as patient medical and mental health comorbidities? | KQ 2. What are the effects of cannabis on health outcomes and healthcare utilization for adults who have PTSD? KQ 2A: Do the effects differ by patient subgroup, such as patient medical and mental health comorbidities? | KQ 3. What are the harms associated with cannabis use in adults? KQ 3A: Do the harms differ by patient subgroup, such as patient medical and mental health comorbidities? | | | KQ 4. What are important areas of ongoing research and current evidence gaps in research on cannabis for chronic pain or PTSD, and how could they be addressed by future research?
| | | Pain or PTSD patients | use/substance use disorder; ▪ Mental health symptoms (not including psychotic symptoms) including depression, anxiety, etc; ▪ Employment; ▪ Weight gain; ▪ Diversion; ▪ Utilization of health services; ▪ Insomnia | ▪ Withdrawal symptoms
| | | [underlined: Exclude:] Imaging findings, lab/blood test results.
Timing | Short- and long-term outcomes
Study design | Systematic reviews, meta-analyses, controlled clinical trials (randomized or non-randomized), and methodologically rigorous observational studies with a comparison group (case-control/cohort studies) that adjust for important confounders. [underlined: Exclude:] Non-systematic or narrative reviews, opinions, case studies, case series, and cross-sectional studies. | | Study designs included for KQ1 and KQ2, plus case series for certain harms (see Outcomes box). [underlined: Exclude:] Non-systematic or narrative reviews, opinions, cross-sectional studies, and individual case reports. | | | Not applicable

To address the efficacy of cannabis in treating chronic pain or PTSD (Key Questions 1 and 2), we examined controlled clinical trials or rigorously designed observational studies with control groups that adjusted for important confounders. Appendix B provides the study selection criteria in detail.

Our study selection criteria to examine harms (Key Question 3) depended on the outcome of interest. In initial discussions within our research group and in consultation with our technical expert panel, we categorized a prespecified list of harms of interest according to whether the likelihood of the outcome might be substantially different in populations with chronic pain or PTSD. For example, we anticipated that rates of depression and anxiety in patients with chronic pain or PTSD were likely to be substantially different than the general population. In contrast, we thought it unlikely that rates of pulmonary effects or cancer would be particularly influenced by the presence of chronic pain or PTSD. We felt that the incidence of adverse cognitive effects and psychotic symptoms in the general population was likely to provide information that was relevant to chronic pain and PTSD populations, though we recognized that, theoretically, chronic pain and PTSD populations might have a different risk. We chose, therefore, to look more broadly at these outcomes but to report population-specific data where available. In an effort to provide clinicians with at least descriptive information about important harms likely to be related to cannabis use whose incidence and relative risk has not been well-characterized, we also included case series and descriptive studies of these “emerging harms,” such as cannabis hyperemesis syndrome and infectious diseases associated with various preparations.

We conducted a primary literature search, but given the broad scope of this review, we summarized data from existing systematic reviews when available to address each question and outcome of interest and then added individual studies meeting inclusion criteria that were published after the end search date of the included review, or were not included in a prior systematic review. We only included reviews that fulfilled key quality criteria: 1) clearly reported their search strategy; 2) reported inclusion and exclusion criteria; and 3) conducted an appraisal of the internal validity of the included trials.^18^ If there was more than one review within each category fulfilling these criteria, we prioritized the most recent review and, if there were several recent reviews meeting quality criteria, we prioritized those with the broadest scope. We discussed the ultimate choice of which reviews to include as a group and resolved any disagreements through consensus.

One of 9 investigators examined titles and abstracts for potential relevance to the key questions using Abstrackr.^19^ We dual-reviewed a random 5% sample of abstracts in order to ensure reliability between reviewers. Two investigators independently reviewed the full text of all potentially relevant articles for inclusion. Disagreements were resolved through consensus using a third reviewer.

## DATA ABSTRACTION

Data from published reports were abstracted into a customized database by one reviewer and confirmed by a second reviewer. From each study, we abstracted the following where available: study design, objectives, setting, population characteristics, subject inclusion and exclusion criteria, number of subjects, duration of follow-up, the study and comparator interventions (formulation, strength, etc), important co-interventions, health outcomes, healthcare utilization, and harms.

## QUALITY ASSESSMENT

Two reviewers independently assessed the quality of each study (Appendix C). Disagreements were resolved through discussion. To assess the quality of trials we used a tool developed by the Cochrane Collaboration.^20^ Each trial was given an overall summary assessment of low, high, or unclear risk of bias. To assess the risk of bias of observational studies we considered potential sources of bias most relevant to this evidence base and adapted existing assessment tools.^21,22^ While there are no validated criteria for ranking observational studies, we chose to assign a summary risk of bias rating to represent confidence in each study's results as follows:

- High risk of bias: studies with one or more methodologic deficiencies which would be considered “fatal flaws”; in other words, an answer of “no” to the question: “Are study results believable, taking study limitations into consideration?” For example, studies with minimal information about the exposure of interest would be considered as having a high risk of bias.
- Medium risk of bias: studies that had important methodologic deficiencies that were not fatal flaws, but should be considered when weighing the strength of evidence. For example, recall bias is an inherent limitation to case-control studies that is important to consider in this evidence base.
- Low risk of bias: studies that had no or minor methodologic deficiencies and reflect the strongest observational study designs.

## DATA SYNTHESIS

We qualitatively synthesized the evidence on the benefits and harms of cannabis. For the subgroup of neuropathic pain studies, we conducted a study-level meta-analysis of the proportion of patients experiencing clinically significant (≥ 30%) pain relief (Appendix D) using the profile-likelihood random-effects model^23^ to combine risk ratios (RRs). We assessed the magnitude of statistical heterogeneity among the studies using the standard Cochran's chi-square test the I^2^ statistic.^24^ All analyses were done using Stata/IC, version 13.1 (StataCorp).

## RATING THE BODY OF EVIDENCE

We assessed the overall strength of evidence for outcomes using a method developed for the Agency for Healthcare Research and Quality's (AHRQ) Evidence-based Practice Centers (EPCs).^25^ The AHRQ EPC method considers study limitations, directness, consistency, precision, and reporting bias to classify the strength of evidence for individual outcomes independently for randomized controlled trials (RCTs) and observational studies, with supplemental domains of dose-response association, plausible confounding that would decrease the observed effect, and strength of association, as well as separate guidance for applicability.^26^ Ratings were based on the following criteria:

- High = Very confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has few or no deficiencies, the findings are stable, and another study would not change the conclusions.
- Moderate = Moderately confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has some deficiencies and the findings are likely to be stable, but some doubt remains.
- Low = Limited confidence that the estimate of effect lies close to the true effect for this outcome. The body of evidence has major or numerous deficiencies (or both). Additional evidence is needed before concluding either that the findings are stable or that the estimate of effect is close to the true effect.
- Insufficient = No evidence, unable to estimate an effect, or no confidence in the estimate of effect for this outcome. No evidence is available or the body of evidence has unacceptable deficiencies, precluding reaching a conclusion.

## PEER REVIEW

A draft version of this report was reviewed by 8 individuals with technical expertise and clinical leadership. Their comments and our responses are presented in Appendix D.