# INTRODUCTION

Cannabis use has become more common among United States (US) adults, with the prevalence of adults reporting past-year cannabis use nearly doubling between 2001 and 2013 to one in 10 adults.^1^ Young adults ages 18-29 are nearly 4 times more likely to have used cannabis in the past year than adults ages 45-64.

The use of cannabis for medicinal purposes has also become increasingly accepted. In California, which was the first state to legalize cannabis for medical purposes in 1996, about 5% of all adults reported having used cannabis for medical purposes in 2012.^2^ In a recent poll, 76% of physicians supported the use of cannabis for medical purposes in certain circumstances.^3^

Eight states and the District of Columbia have legalized cannabis use for recreational purposes, and 28 states plus the District of Columbia have legalized cannabis for medical purposes. Both houses of Congress recently passed H.R. 2577, which would allow federally-employed physicians working for the Veterans Health Administration to recommend cannabis for medical purposes to Veterans if appropriate in states that have legalized its use.^4^

The conditions that would qualify a patient to use cannabis for medical purposes differ across states, but nearly all include chronic pain itself or diseases which are likely to cause chronic pain (such as multiple sclerosis [MS]-related spasticity). Several states also list post-traumatic stress disorder (PTSD) as a qualifying condition, which is of particular importance to Veterans and, indeed, was one of the rationales cited for the genesis of H.R. 2577.

Approximately 30% of Americans currently experience chronic pain,^5^ a figure that is estimated to increase as the population ages and manages more chronic medical conditions.^6^ Recent studies suggest that 45-80% of individuals who seek cannabis for medical purposes do so for pain management^7,8^ and among patients who are prescribed long-term opioid therapy for pain, an estimated 6%-39% are also utilizing cannabis.^9,10^

Recent research suggests that over one-third of patients seeking cannabis for medical purposes in states where it is legal list PTSD as the primary reason for the request.^11^ Approximately 15% of Veterans who are treated in Department of Veterans Affairs (VA) outpatient PTSD clinics report recent (past 6 months) cannabis use.^12^

In the past, use had been limited to inhalation or ingestion of parts of the whole plant of the genus Cannabis. More recently, many more formulations of cannabis have become available in recreational and medical cannabis dispensaries including an array of edibles, oils, tinctures, as well as plant extracts with varying ratios of the 2 active ingredients of cannabis: tetrahydrocannabinol (THC) and cannabidiol (CBD). There are also 2 purely synthetic cannabinoids available in the US by prescription only (dronabinol and nabilone).

Given the social, political, and legal changes surrounding cannabis use, physicians in both VA and non-VA settings will increasingly need to engage in evidence-informed discussions with their patients about the potential benefits and harms of cannabis use. Despite the rapidly moving legislative landscape, there is little comprehensive and critically appraised information available about what is known and not known about cannabis use for the treatment of chronic pain or PTSD.

The objectives of this systematic review are to: 1) assess the physical and mental health outcome effects of cannabis in patients with chronic pain; 2) assess the physical and mental health outcome effects of cannabis in patients with PTSD; 3) assess the impact of short- and long-term cannabis use on the risk of adverse effects such as pulmonary diseases, cardiovascular diseases, cancer, cannabis use disorder (CUD), and psychosis in the general adult population; and 4) provide a broad overview of more recently recognized “emerging harms” of cannabis use.