# APPENDIX D PEER REVIEWER COMMENTS AND AUTHOR RESPONSES

Rev # | Comment | Response
Are the objectives, scope, and methods for this review clearly described?
1-7 | Yes | Noted.
9 | No - page 4, line 35: please add risk of cannabis use disorder to the list of adverse events in this phrase-“assess the impact of short- and long-term marijuana use on the risk of adverse effects such as pulmonary diseases, cardiovascular diseases, cancer, and psychosis in the general adult population” | This change has been made.
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked?
1, 2, 4, 7 | No | Noted.
3 | Yes - There is a recently published systematic review of medical marijuana in psychiatric indications (Wilkinson et al., 2016) that wasn‧t included. This may have been a timing issue. But now that it is published, it should be included - especially since it informs the PTSD literature. | We have added information from this recent systematic review to our report.
5 | Yes - A couple of studies regarding harms have come out since your February 2016 deadline. Considering that the review is not likely to be formally published much before 2017. I uploaded the pdfs of these papers.; - One is a new analysis of the Dunedin study showing that cannabis users are more likely to develop periodontal disease.; - The second one is an epidemiologic study from Sweden that shows an association between early, heavy cannabis use and mortality. | We added the new Dunedin analysis to the emerging harms section. We had assessed another analysis from the Swedish military conscript study – there was no data on ongoing tobacco or cannabis use after conscription and, since the outcomes were many decades later, the lack of exposure information made the study results very difficult to interpret.
6 | Yes - See Review. | We have reviewed the studies you suggested and included them in our report if they met our inclusion criteria or if they were relevant for background and discussion sections.
9 | Yes - In assessing risk of harm, it would be more appropriate to include studies assessing harm among daily marijuana users (whether or not they have pain or PTSD) than to assess risk of harm amongst pain or PTSD patients who do not use or who occasionally use marijuana. | We broadly included studies with varying levels of use (including heavy use) and in broad patient populations. We have clarified throughout the summary table and manuscript whether the results apply to light or heavy use and we have clearly noted when there is a lack of data on heavy (daily) use.
Is there any indication of bias in our synthesis of the evidence?
1-5, 7 | No | Noted.
6 | Yes - The choice of only including plant-based and not synthetic cannabinoid studies seems biased, given that they have the same molecular structure. | We have rewritten the methods and the KQ1 results section to better clarify the rationale for this decision and we note how the exclusion of synthetic cannabinoid studies would likely not have affected our overall findings (since there were no large, good quality studies of synthetics in the populations of interest for this report).
9 | Yes - There appears to be a bias in favor of state-approved retail marijuana products for treatment of pain and PTSD. The executive summary introduction states that the purpose of the paper is to examine health effects of marijuana use because of increased state legalization of marijuana plant products for the indications of pain and PTSD, but the review of the literature conflates studies of plant-based pharmaceutical grade products (i.e. Sativex) with those of retail smoked marijuana and other marijuana products. As written, the two types of cannabis products are conflated in the summaries of the evidence and in the recommendations. The differences between the two types of products need to be clearly explained and then considered separately in all of the analyses. While Sativex is not currently FDA-approved, it is approved as a pharmaceutical in other countries, is manufactured to known standards of purity and potency and is therefore distinct from retail marijuana products. I recommend a clear explanation in the introduction of the differences between pharmaceutical products manufactured to specific potency and purity versus retail marijuana products. THC and cannabidiol concentrations vary widely in retail marijuana. The trend toward higher THC and lower cannabidiol in retail marijuana renders studies of lower THC/higher cannabidiol pharmaceuticals and plant products irrelevant or only indirectly relevant to many currently marketed marijuana products. Given these differences, the level of evidence should be appropriately downgraded for “indirectness” when citing studies of cannabinoid pharmaceuticals, as these do not directly address the benefits and harms of smoked marijuana or other retail marijuana products. | We agree. We have added language to the results clarifying that most studies examined preparations with precisely defined THC/CBD content. We also added to the applicability section in the Executive Summary and main report that preparations studied may not reflect what is widely available in dispensaries, and we added a reference to a study that suggested measured content differed from labeled content in dispensaries. Finally, we added the issue of applicability to the rationale for strength of evidence in the summary of evidence table.
9 | In assessing potential risks, studies of “low to moderate use” are not appropriate for inclusion. When used for medical purposes, the usual pattern is daily consumption. Therefore, in order to evaluate potential risk, only studies that systematically assess for risk among daily users would be relevant to the question of potential harm from medical use. At least one cited study includes cannabis non-users in the denominator when reporting rates of cannabis use disorder among patients with pain, and is therefore implies a much lower risk of cannabis use disorder than would be expected among daily “medical marijuana” users. | With regard to the cannabis use disorder studies, we agree that we did not clearly describe the cited study and the limitations in the overall evidence base. We revised this section to clearly state that there were no studies in cannabis users. We also de-emphasized the cross-sectional data in chronic pain users in the summary of evidence section since these were not studies in a cannabis-using population. With regard to the other harms, we were broadly inclusive in part because clinicians may encounter a broad range of use among patients. We were careful to describe the evidence as being applicable to low levels of use (as with effects on pulmonary function) when appropriate, and added clarification on the lack of data (or even potential for harm in case of pulmonary function) with heavy use.
Additional suggestions or comments.
1 | Excellent review. Clarify on page 4 and in methods the reasons for choice in key exposure (e.g., what is typically found at dispensaries, and not synthetic forms that have been systematically reviewed already) | See above.
2 | My comments are all fairly minor. 1. A brand name, “Sativex,” is used many times in tables and intermittently throughout the text. I believe the generic name (nabiximols) should be used instead in all text and tables. | We agree and have made this change.
2 | 2. Page 6, line 18 (also page 18, line 39): “and an estimated 6.2%-39% of chronic pain patients are utilizing cannabis in addition to opioid medication for pain management.” The denominator is unclear in this sentence. Should it be “among patients on opioid medication for chronic pain, 6-39% also use cannabis”? | This language was clarified.
2 | 3. Page 6: The introduction alternates between “marijuana” and “cannabis.” Is there any distinction? If not, I suggest selecting a preferred term and using it consistently for clarity. | We agree and have changed it to “cannabis” throughout.
2 | 4. Page 6, Methods: A brief rationale for the decision to exclude synthetic cannabinoids would be helpful. | This has been added.
2 | 5. Page 66, last paragraph of discussion: When considering implications for pain management, it seems appropriate to mention that multiple pharmacological and nonpharmacological therapies have stronger evidence for chronic pain than either cannabis or opioids. Given the state of the science on cannabis and the existence of many efficacious medical and complementary therapies for pain, I am aware of no scientific rationale for singling out cannabis as an important “opioid sparing” therapeutic option. (This is a common line of argument for increasing cannabis availability, so I don‧t fault the authors for mentioning it.) The first recommendation from CDC guidelines on opioid prescribing, as well as treatment guidelines for common conditions such as back pain and arthritis, could be cited here. | We added language from the 1^st^ recommendation in the CDC guidelines. We also added references and language about other evidence based pharmacologic and non-pharmacologic therapies.
3 | Overall this is a very thorough review. The risks of psychosis are underestimated and understated. There is a body of evidence that exposure to cannabis is associated with a risk for a psychotic disorder. There is an entire special issue of Biological Psychiatry (April, 2016) dedicated to cannabinoids and psychosis. The authors are strongly urged to review this special issue. There is robust evidence (unlike what the review states) of direct experimental evidence that cannabinoids at certain doses can induce psychosis-like effects in healthy individuals and that cannabinoids can exacerbate psychosis in individuals at risk for or with an established, psychotic disorder. Restating the risk of psychosis is important because of the numbers of veterans with SMI who seek out certification for medical marijuana. I see a number of veterans diagnosed with chronic psychotic disorders who have asked for medical marijuana certification from VA doctors. They go to non-VA providers get a card, start using marijuana and end up in the hospital. While this is anecdotal, stating that the link to psychosis is “low” or “entirely observational” is not without risk. | We generally agree, though we have to stick to the strength of evidence grading approach we have used throughout the report – we did include mention of experimental studies, though they were small and had some methodologic flaws. However, we had not incorporated these into the summary statement – we have changed this and clarified the extent of evidence. The SOE rating is low because much of the evidence is observational (though not entirely), it is difficult to know the magnitude of effect, and there is little data specific to chronic pain and PTSD populations – we have clarified this rationale throughout.
5 | Obviously, compiling all the papers need to generate this review took a lot of effort. Overall, the review seems comprehensive and generally accurate. When fully refined, it will make an important contribution to our knowledge base. There is some sloppiness in the preparation as though the draft did not undergo careful and extensive proofreading before being sent out for review. In certain presentations of various studies there is a lack of needed detail and occasionally lack of rigor in interpretation. Most of the examples of these concerns that I could find are detailed below, but I cannot confirm that this list is exhaustive of all miscues. | Thank you for the suggestions – we have detailed our responses below and additionally went through the entire report and did an additional round of copyediting.
5 | Page 5, lines 12-13: The assumption that rates of pulmonary effects or cancer would not be influenced by presence of PTSD or pain seems flawed at least on the basis that individuals with these disorders use tobacco at higher rates than the general population, and tobacco and cannabis might have additive or synergistic effects. In addition, it seems likely that both PTSD and pain might have subtle hormonal or immune system effects that could interact negatively with cannabis use. | We agree that there is some risk in considering studies in broader populations. We did so after considering likely important confounding factors as related to chronic pain or PTSD. We agree tobacco use is an important confounder and levels might be higher in chronic pain or PTSD populations, but the studies that contributed findings all accounted for tobacco use (and usually conducted analyses among never smokers etc) – studies that did not adequately control for tobacco use were downgraded in quality and did not contribute to findings. There are certainly other factors that might theoretically confound findings – we have added to the limitations section this issue (and, in general, this is one of the reasons why bodies of evidence based only on observational data typically start with a lower strength of evidence rating).
5 | Page 5, line 45: Change “size” to “sizes.” | We have made this change.
5 | Page 6, lines 4-13: Given the nature of the uncontrolled studies reviewed, it would probably be better to say that “cannabis is potentially associated with either harmful or neutral effects” rather than is potentially harmful. | We have made this change.
5 | Page 8, line 36: Change “is” to “are.” | Done
5 | Table (Page 9): Calls medication Sativex when text calls it nabiximols. Should use generic name throughout document to be consistent. Acronym ROB should be footnoted to explain it to anyone perusing the table. | Done
5 | PTSD: It seems incorrect to say that marijuana is potentially harmful since these studies were observational. Is it likely the marijuana is causing more violence and use of other substances? Possibly, but it seems more intuitively probable that patients who are more violent and certainly who use other substances are more likely to use marijuana. It is more credible to say that there is no evidence that it is helpful. | We changed the executive summary paragraph accordingly. There is more detail in the main body of the report, but the strength of evidence related to bias and small number of studies is clearly indicated.
5 | Page 21, lines 54-57: This sentence does not make sense. If they inhaled a 25 mg dose, the per cent THC is irrelevant because the dose would be the same. What is the preparation here? It does not sound like herbal marijuana. | Language regarding the preparation was clarified; it was indeed an herbal preparation obtained from Prairie Plant Systems Inc. (Saskatoon, Sask.). Regarding dose and potency, this is the language that the authors use to describe the potency and dose. The 0% THC was prepared using “ethanolic extraction of cannabinoids” (see Ware 2010 pg. E695). Concentrations/potencies (percent THC) were varied, but were delivered in the same dose (25 mg).
5 | Page 22, lines 42-59: This study is very poorly described. The reader needs to know more about the cannabis product used. If the study was observational, how was assignment to condition determined? The word “native” should be “naïve.” | Cannabis product described in more detail. Assignment to conditions described in more detail. Native changed to naïve.
5 | Page 23, lines 7-21: These studies are also exceedingly poorly described. What were the basic study methodologies? | Designs for both studies were described in more detail.
5 | Table 3: How can the Wilkinson study be medium risk of bias? Shouldn‧t it be high risk of bias? Obviously, the participants self-selected into their groups. We know that people who use marijuana are more likely to use alcohol and vice-versa. Most likely individuals with PTSD and a propensity to violence are more likely impulsive and more likely to use marijuana. The marijuana may not be causing the violence. The p-value given for primary outcome of Johnson study is inconsistent with what the text says. | We used a standard risk of bias tool to evaluate the observational studies (Newcastle-Ottawa Scale), and using this tool classified the study as medium risk of bias (individual item scores are included in the Appendix C PTSD risk of bias table). This particular study adjusted for confounders which contributed to the medium rating. We agree that causation is very difficult to assume here and this is part of what contributes to rating the body of evidence as insufficient. Regarding the Johnson et al. paper, we have checked the values and confirmed that those reported in our table correspond to those reported in the paper.
5 | Page 26, lines 21-23: Serious adverse events mentioned twice with different ORs. | Thanks – this was a typo and was corrected (last should have been withdrawal due to AE).
5 | Page 26, lines 25-26: Information on specific serious adverse events should be provided in more detail. It is hard to see how paranoia or agitation by themselves would meet the FDA definition of serious adverse event unless they resulted in hospital admission. | We believe the section provides the detail we have available, while remaining circumspect about the seriousness of most of the short-term adverse events reported. The definition of serious adverse event is not provided in the Whiting review or its review protocol. We do clarify that many of the side effects were minor and common effects of cannabis. We have rewritten the sentence and taken out the modifier “serious”. The definition of serious adverse events includes medical events for which an intervention might be necessary to prevent something like hospitalization – this is obviously somewhat at the discretion of the monitoring board and investigators and we simply report what the review authors reported.
5 | Page 26, line 34: add “and” between “pain” and “found.” | This change has been made.
5 | Page 34, line 13: Change “was” to “were.” | This change has been made.
5 | Page 36, line 8: Describe dose and route of administration of cannabis in this study. | This change has been made.
5 | Page 37, line 42: Delete “…who were diagnosed with CUD.” | We have left this statement in the text for clarification.
5 | Page 38, lines 4-15: An apparent issue with the Bonn-Miller study described here which may warrant mention is that the Veterans who had CUD and checked into an inpatient unit presumably had to undergo cannabis withdrawal absent any treatment for it. Was it their CUD per se or the withdrawal symptoms (or both) that interfered with their treatment improvement? It would be good to know also if their PTSD severity at treatment entry was equivalent to that of the non-CUD group. | Our summary describes the results and adjustments for confounders, but we have not included a discussion about whether or not withdrawal symptoms vs CUD was responsible for the findings because it is not possible to determine based on the methods.
5 | Page 40, line 7: Change “abuse” to “misuse.” | This change has been made.
5 | Page 41, line 4: Remove “is.” | This change has been made.
5 | Page 42, line 47: Need route of administration of cannabis oil. | This was not specified in the ClinicalTrials.gov entry; we have clarified this in table.
5 | Page 43, line 42: 0 mg does not make sense. | This is what was reported in the ClinicalTrials.gov entry, but we have clarified (it was a titration up to 250 mg).
5 | Page 52, Table 8: Additional suggestions: All clinical trials of cannabis should obtain blood levels of THC and CBD so that there is some objective measure of how much drug exposure has occurred. Almost all studies done thus far have been quite low dose. Thus, higher doses must be tested. CBD should be much better studied acutely and longitudinally to determine whether it is reinforcing and whether tolerance and withdrawal occur with chronic use. | Thanks, this has been added.
6 | Excellent work! Remaining points to consider are highlighted below… Major Issues: 1. One of the larger issues with the report, as written, is the choice to exclude “synthesized, pharmaceutically prepared cannabinoids (e.g., dronabinol, nabilone).” The authors chose to include studies of whole-plant or plant-derived cannabinoid preparations, but synthetic preparations with the same exact molecular structure and delivery method were excluded. There are very few organizations that produce plant-derived cannabinoids (e.g., NIDA, GW Pharmaceuticals), whereas synthetic cannabinoids (e.g., dronabinol, nabilone) are not only more widely available to researchers, but have been produced and used in research for quite some time. Without a clear rationale, which I think would be difficult to make, the choice of excluding synthetics appears to introduce bias particularly as a number of studies on pain and PTSD have utilized synthetic preparations. For example, Jetly et al., 2015 conducted a pilot RCT of nabilone for PTSD and nightmares, Fraser (2009) conducted a chart review of 47 patients diagnosed with PTSD who received nabilone, and Roitman et al., 2014 conducted an open-label trial of oral THC for PTSD symptoms. While there is currently debate regarding the necessity of using plant-derived versus synthetic cannabinoids in research and treatment, the heart of this debate lies in the importance of secondary cannabinoids and terpenes, which are present in plant-derived products and not in synthetic ones. As it is unlikely that the role of these secondary compounds informed the selection criteria, given that secondary cannabinoids and terpenes are not even reported in the studies discussed in this review, it seems as though it would be difficult to provide a compelling case for this choice. | We added rationale in methods section. We also added information to both the chronic pain and PTSD section regarding the findings from recent systematic reviews on synthetics as they relate to our populations of interest. There was an SR published that included PTSD data very recently – while it was published after our search dates ended, we did include a description of the review and the studies relevant to PTSD. We added discussion of the applicability of the synthetic studies to our questions of interest – there was only one trial of nabilone with very few patients – the other studies would not have met inclusion criteria. Regardless, even after considering all the additional studies, the authors of the recent SR came to the same conclusion re: insufficient evidence.
6 | 2. An additional consideration for the section entitled “Emerging Harms” could be the recent proliferation of new methods of cannabinoid delivery and the resulting risks of adverse events. For example, the use of “dabs” appears to be associated with particularly heightened risk of tolerance and withdrawal (e.g., Loflin & Earleywine, 2014), and the use of edibles with a number of more acute consequences (e.g., Hudak et al., 2015; Lamy et al., 2016). | We added this information to the emerging harms section.
6 | 3. While the authors are correct in stating that the majority of the literature describes the effects of “cannabis” or “marijuana” without a clear definition of the cannabinoid profile of the product tested or used, the authors similarly make broad comments about consequences of “cannabis,” where a more nuanced understanding is emerging. For example, the authors discuss a negative consequence of cannabis use as being psychosis. While this is indeed a finding that has been described in-depth within the literature, and even tied to a genetic vulnerability (i.e., catechol-O-methyltransferase), emerging evidence suggests that the association between cannabis and psychosis is specific to THC and that CBD can actually provide anti-psychotic effects (e.g., Leweke et al., 2012). This level of nuance is not currently provided in the review. | We agree. We have added clarification that it is the THC component that is most likely to be associated with psychotic symptoms and we added a statement to the discussion that CBD has actually been studied as an antipsychotic agent.
6 | 4. Somewhat related to the inclusion and selection of studies for the review, it is puzzling that the Bonn-Miller, Boden, Vujanovic, & Drescher, 2013 study was not included in the list of studies of the effects of cannabis on PTSD symptoms. That study appears to meet inclusion criteria as it was prospective, involved validated measures of PTSD (i.e., PCL), and included a comparison group (CUD diagnosis was compared to those without CUD diagnosis). The sample was adults and there is no indication that they used synthetics. While the study did use data from medical records, so did the administrative study by Wilkinson et al., 2015. This is just confusing. | Although this study included a control group, the controls didn‧t have CUD, but might have used cannabis; therefore, it did not meet our criteria because we were comparing studies with a non-cannabis using control group.
6 | 5. On page 7, the authors note that they “…did not find any literature comparing rates of CUD among individuals with chronic pain or PTSD to rates in other populations…” While this may be true, a study by Bonn-Miller, Harris, & Trafton (2012) documented the prevalence of PTSD among Veterans with CUD (29.05% in FY12), and a VA fact-sheet by Bonn-Miller & Rousseau utilized VA PERC data to document the percentage of Veterans with PTSD-SUD who had a CUD diagnosis (22.7% in FY14). These data seem to provide information close to what the authors note as being missing from the literature. | Although these studies don‧t meet inclusion criteria, we have added the 2012 data on prevalence to the background paragraph of our CUD section.
6 | Minor Issues: 1. The authors switch between using the terms “cannabis” and “marijuana.” The manuscript may flow more nicely if consistent terminology was used throughout. Indeed, the term “cannabis” is generally preferable over “marijuana.” | We agree and have made this change.
6 | 2. p. 7: “…found that about 2% if Veterans with non-cancer…” should be “…found that about 2% of Veterans with non-cancer…” | This change has been made.
6 | 3. p. 46: The description of the study by Eades et al. within the text is not consistent with the table. The table is correct and the text is inaccurate. The text should note that the three groups are “High/Low, High/High, and Low/Low”. | This change has been made.
6 | 4. p. 46: “…marijuana use versus no marijuana use in the past 6 months is associated with PTSD symptoms and sleep” should be “…marijuana use versus no marijuana use in the past 6 months is associated with differential trajectories of PTSD symptoms over the course of a year.” | This change has been made.
6 | 5. p. 48: Replace “In addition, we obtain lab analysis results of the cannabis donated through the Santa Cruz Veterans Alliance to the Veterans. This includes lab analysis results of percent cannabinoids within each product.” with “In addition, all product provided to Veterans by the Santa Cruz Veterans Alliance is tested for cannabinoid content by an independent laboratory.” | This change has been made.
6 | 6. The authors cite one of the two epidemiological studies of cannabis and PTSD (i.e., Kevorkian et al., 2015), but not the earlier study conducted among the NCS-R (i.e., Cougle et al., 2011). | The Cougle et al. study only reports data on cannabis use, not CUD, and therefore is not included in this section.
7 | I was primarily interested/knowledgeable of the evidence for its use in PTSD and think that you did an excellent job reviewing that sparse literature and mentioning the fact that there are two current RCTs in progress that will add to the literature. Overall, very nice job and I have no further suggestions. | Noted.
9 | Page 6-line 20. “There is low strength evidence that low levels of marijuana smoking do not adversely impact lung function over about 20 years in young adults.” Low levels of marijuana smoking are irrelevant to the question of possible harm associated with “medical” that is, frequent/daily use. | We included any data regarding harms from studies that met inclusion criteria. We clearly state that these data apply to low level users and not daily users. We feel that the breadth of evidence will be useful to clinicians who can assess patients‧ frequency of use and decide whether or not the available data apply to an individual patient. While it is likely that many patients using medical marijuana do so daily, we do not know this to be universally true and there may be substantial proportion of patients who use less frequently. In any case, the lack of information in older or multimorbid populations (which we clearly state) is perhaps an even bigger issue in applying the data in VA clinical settings – again, we attempted to present our broadest look at harms with clarification on generalizability issues.
9 | Page 7-line 38. Recommend deleting this sentence: “One large cross-sectional study of Veterans found that about 2% if (sic) Veterans with non-cancer pain had a diagnosis of CUD, and that this increased to 4%…” This is irrelevant to the question of the risk of cannabis use disorder among patients using marijuana for chronic pain treatment who would more likely use it multiple times daily. If it is possible to discern from the paper the prevalence of CUD among those with pain who used marijuana to treat pain, that would be worth mentioning. THC concentration would also be important to note, as more potent varieties (10 - 20+%) currently marketed would pose a greater risk for CUD than the more common low potency (3%) of a decade ago. | We have corrected this sentence and provided this information (as well as some additional, new information) on prevalence as part of our background.
9 | Page 8-line 30. Ibid. “Light to moderate use” is irrelevant to the question of harm among daily users. | We have clarified that the data does not apply to heavy (daily) users.
9 | Page 8 line 34- also needs to include cannabis use disorder among the serious mental health adverse events. Including indirect evidence about the risk of cannabis use disorder among daily users would better inform decision-making than the indirect study of pain patients who have not used marijuana. | We rewrote the sections on CUD to clarify that there was no evidence with which to assess rates of CUD, and we mention cross-sectional data.