# APPENDIX C QUALITY ASSESSMENT

Cochrane Risk of Bias (ROB) Assessment Criteria for Trials^20^

Domain | Criteria
Sequence generation | Was the allocation sequence adequately generated?
Allocation concealment | Was allocation adequately concealed?
Blinding | Was knowledge of the allocated intervention adequately prevented during the study?
Incomplete outcome data | Were incomplete outcome data adequately addressed? Consider attrition, intention-to-treat analysis
Selective outcome reporting | Are reports of the study free of suggestion of selective outcome reporting?
Other sources of bias | Was the study apparently free of other problems that could put it at a high risk of bias (ROB)?
Overall assessment of potential for bias | Low/Unclear/High

Trials in Patients with Chronic Pain – Risk of Bias (ROB) Assessment

Study; Pain type | Sequence generation | Allocation concealment | Blinding | Incomplete outcome data | Selective outcome reporting | Other sources of bias | Overall: Low/Unclear/High ROB
Abrams, 2007 ^35^ HIV-associated sensory neuropathy | Yes: Randomization (1:1) to cannabis or placebo cigarettes was computer-generated by the study statistician | Yes: allocation managed by an independent research pharmacist | Yes: Treatment was double-blind, NOS. The National Institute on Drug Abuse provided identically appearing pre-rolled cannabis and placebo cigarettes | Yes: Low loss to follow-up. | Probably yes. Does not state protocol was reported prior to study. | Yes | Low
Berman, 2004 ^36^ Neuropathic Pain from Brachial Plexus Avulsion | Yes - computer generated list | Unclear | Uncertain; notes that treatment sequence was blinded via sealed code break envelopes but no further details given | Yes: ITT analysis, attrition described | Unclear: No protocol mentioned, but outcomes reported in the methods are included in results | Unclear: No washout period between treatment regimens | Low
Blake, 2006 ^59^ Rheumatoid arthritis | Unclear (permuted blocks of four) | Unclear (not reported) | Unclear (not reported) | Yes: low attrition, comparable across groups | Yes | Unclear (COI statement notes the study was funded by a drug company) | Unclear
Collin, 2010 ^47^ MS | Unclear, method not described | Unclear, method not described | Probably yes, but not described in detail | Yes: ITT | Yes | The data on pain is limited only to spasticity responders. | Unclear
Corey-Bloom, 2012 ^48^ MS | Unclear, method not described | Unclear, method not described | Yes: identical placebo cigarettes | Yes: < 80% attrition; also did worst case scenario analysis | Yes | Excluded high doses of narcotic medications for pain, but did not control for or examine concomitant use of analgesics because spasticity was primary criteria and outcome of interest. No mention of analgesic use for pain. | Unclear
De Vries, 2016 ^58^ Abdominal pain | Yes: computer-generated randomization list stratified for opioid and non-opioid users by using separate lists | Yes: central allocation (“Independent pharmacists dispensed either active or placebo tablets according to a computer-generated randomization list”) | Yes: “Treatment allocation was strictly concealed from participants, investigators, and all other study personnel involved in the study until end of study and database lock.” | No: ITT analysis not performed | Unclear: for several secondary outcomes (depression, quality of life, EEG, etc), researchers simply stated “did not change after THC treatment compared with placebo” but did not give any values. | No power calculation, likely inadequate power to detect differences. Also, what was originally supposed to be 2 trials were combined into one study “because of a disappointing recruitment.” | High
Ellis, 2009 ^37^ HIV-associated sensory neuropathy | Yes: Randomization was performed by a research pharmacist using a random number generator, and the key to study assignment was withheld from investigators until completion statistical analyses. | Yes: key was withheld from study investigators until completion of analysis. | Yes: double blind, cigarettes “were constructed of the same base material.” Assessed effectiveness of blinding among participants | Moderate: 6/34 lost. ITT. Similar baseline characteristics. | Yes: all outcomes in methods were reported. | This is a specific population of HIV pain; Patients allowed to use own analgesia; Used validated scales for pain measures | Low
Johnson, 2010 ^55^ Cancer | Not described; Table 1 shows general similarities between groups but baseline opioid use was lower in one group vs others | Not described | Not described for investigators; Yes for patients; bottles were similar between active and placebo, though patients on active were able to guess their group | Yes; ITT done and overall attrition >80%, though one group lost >80% | Yes | This is a specific population of cancer pain; Patients allowed to use own analgesia; Used validated scale and self-reported scale as co-outcomes for pain | Unclear
Langford, 2013 ^49^ MS | Yes: “Randomization occurred using a pre-determined computer-generated randomization code in which treatment allocation was stratified by center, and used randomly permuted blocks of variable sizes.” | Yes | Yes: double-blind | Yes - ITT, but in group A, 26/167 (cannabis) and 16/172 (placebo) withdrew. | Yes: outcome measures reported | No: Strong placebo effect; Placebo group patients who titrated to the maximum dose had disproportionate improvements in pain scores, and a number of these patients reached the maximum permitted dose as the study period was drawing to a close. Self-titration combined with a subjective endpoint seems therefore to have significantly impacted the placebo response. | Unclear
Lynch, 2014 ^38^ Chemotherapy-Induced Neuropathic Pain | Yes | Yes | Yes | Yes (16/18 completers) | Yes | Yes | Low
Notcutt, 2004 ^33^ Mostly neuropathic; 47% MS | Yes | Yes: randomization done externally | Yes: trial stated as being double-blind and delivery of intervention and placebo were matched | Unclear: for the trial portion, 71% (24/34) patients were included in analysis due to withdrawal/use of rescue meds | Yes | Excluded those who had to use rescue medications; also, only randomized pts who reported a positive response to medical cannabis. | Low
Notcutt 2012^29^ | Yes: independent statistician produced an allocation schedule using balanced permuted blocks of 4 with computer-based algorithm | Yes: independent statistician | Unclear: no methods described | Yes: had high attrition (∼50%) and only some subjects met treatment failure but based on disposition tree, all included subjects were analyzed | Yes: appeared to report on relevant outcomes | No: underpowered (though CI adjusted to help with this), some participants restarted on their own nabiximols prior to final assessment (likely to reduce the effect of the drug) | Unclear: multiple areas of uncertainty; study was underpowered and patients could have restarted nabiximols prior to assessment
Novotna 2011^27^ | Unclear, methods not described | Unclear, methods not described | Unclear: states that trial was double-blind but no details on methods; comment that inclusion into trial based on investigator assessment that patient remained blinded during initial phase of study | Yes: ITT though patients without post-randomization efficacy data were excluded, all patients who had received one dose of medication included in safety analyses; attrition reported (12% for nabiximols group and 2% for placebo). | Yes: had clearly stated pre-specified primary outcome and included multiple secondary outcomes | Yes: no major issues identified aside from lack of clarity around the methods used for allocation, randomization | Low: though limited data on methodology around allocation and blinding, authors state that study was double-blind and had low attrition with ITT analyses and pre-specified outcomes
Noyes, 1975 ^56^ Cancer | No | No | Yes (patients), No (providers) | Unclear, though 34/36 patients were reported to be completers. | No (only reported results for significant tests, refer to “other differences” that did not reach significance) | Pain measure not validated | High
Nurmikko, 2007 ^39^ Neuropathic Pain Characterised by Allodynia | Yes: “randomly permuted blocks stratified by center and was generated using a computer based pseudorandom number algorithm” | No: a copy of randomization schedule in patient-specific sealed envelopes sent to the pharmacy in each center | Yes | Yes: ITT analysis, attrition described | Unclear: no protocol mentioned, but outcomes reported in the methods seem to be included in results | Unclear: “GW Pharma acted as the sponsor of the study, provided the medication, participated in the study design, coordinated the study between centers and carried out the first set of analyses. The analyses were verified by an independent statistician.” | High
Portenoy, 2012 ^57^ Cancer | Unclear | Unclear | Yes (patients), Unclear (research staff) | No (attrition 27%) | Yes | Yes | Unclear
Rog, 2005 ^50^ MS | Yes: “Patients were randomized using a predetermined randomization code drawn up by a statistician who remained unknown to study personnel throughout the duration of the trial.” | Yes: “statistician remained unknown to study personnel throughout the duration of the trial….Treatment allocation was made using randomized permuted blocks of four (two active drug, two placebo), with treatments sequentially assigned.” | Yes: double-blind, and “Placebo was designed to match the appearance, smell, and taste of the active formulation but contained no active components, in ethanol: propylene glycol (50:50) excipient. To facilitate blinding, patients completed pain and sleep | Yes: only 2/64 did not complete. Both received cannabis - one adverse event, one withdrew consent. ITT. | Yes: all outcomes reported in methods were reported. | Unclear: Required no change of concomitant meds, but no mention of controlling for meds/sensitivity analysis, or analyzing by med class. | Low
Selvarajah, 2010 ^40^ Diabetic Neuropathy | Unclear: no information other than saying it was randomized | Unclear: no information | Unclear: no information about blinding except stating that it was a double-blind trial | Unclear: completed ITT analysis included but 1 patient with protocol violation was excluded. | Unclear: states “Tolerability and side effects were evaluated using standardized forms” but does not report these results (except saying 6 patients overall withdrew due to AEs). Unlikely to have introduced significant bias. | No power calculation reported, very likely the study had inadequate power to detect differences | Unclear
Serpell, 2014 ^41^ Peripheral neuropathic pain (PNP) associated with allodynia | Yes: a predetermined computer-generated randomization code | Unclear | Yes | Yes: ITT analysis, attrition described | Yes: protocol available (https://clinicaltrials.gov/ct2/show/NCT00710554), study reports all outcomes mentioned | Recorded medications used; also did allodynia testing | Low
Van Amerongen, 2017 ^51^ MS | Unclear: randomization schedule prepared by independent statistician; allocated “on the basis of the date of eligibility of the individual because the identification numbers are assigned at that moment.” | Unclear: “The schedule was sent to the hospital pharmacy, and sealed envelopes for code breaking were available for the investigator”; opaque envelopes not specified | Yes: matching placebo tablets, “All staff involved in the clinical execution of the study were blinded until all data were collected and the database was locked.” | Yes: attrition with reasons reported by group, and ITT analysis performed. | Unclear: the McGill Pain Questionnaire was mentioned as a secondary endpoint in the online protocol and Methods section, but was not reported in the Results. | Yes | Unclear
Wade 2003 ^30^ MS (67%) | Yes: sequence generated with Williams squares | Yes: stated that participants and staff were blinded. | Yes: identical sprays used with masking flavor; investigators were not aware of coding | Yes: attempted to analyze those who took rescue medications vs entire sample | Yes: looked at range of symptoms | Small sample size | Low
Wade, 2004 ^52^ MS | Unclear: permuted blocks of 4, stratified by primary symptom and center | Unclear: the pharmacist at each center was provided with a randomization scheme and assigned the treatments in sequential patient number order | Unclear: investigators did not assess the degree of blinding of patients and outcome assessors, though a stronger effect was found for pain outcome in placebo compared with active treatment. | Yes | Unclear | Unclear: study was underpowered for pain outcome | Unclear
Wallace, 2015 ^42^ Diabetic Neuropathy | Yes: “Randomization was performed by a research pharmacist using a random number permutations...” | Yes: “Randomization was performed by a research pharmacist using a random number permutations and the key to study assignment was withheld from investigators until completion of statistical analyses” | Unclear: blinding may have been compromised due to crossover design and euphoria from the drug, but analyses didn't find this to be significant | Yes: did not appear to be any missing data; one patient only participating in some of the sessions were only analyzed for those sessions | Yes: reports the outcomes mentioned in the CT.gov protocol (https://clinicaltrials.gov/ct2/show/NCT00781001) – although some of results are mostly in charts which may make it hard to abstract all data accurately | Study only enrolled 16 patients, rather than 20 in power calculation. Also, only very short-term | Low
Ware, 2010 ^43^ Post-surgical or post-traumatic neuro-pathic pain | Unclear (just notes a Latin Square design) | Unclear (not reported) | Yes (notes factors to maintain blinding such as placebo comparability confirmed by objective assessment) | Yes (very low attrition) | Yes | Yes | Low
Wilsey, 2008 ^44^ Neuro-pathic pain | Yes | Yes | Uncertain: no details given on blinding, beyond statement to the effect | Yes: Attrition <80% for all arms; all available data used in analysis | Yes | Pain scales were self-report; also used neurocognitive testing and evoked pain threshold | Low
Wilsey, 2013 ^45^ Neuro-pathic pain | Yes | Yes | Uncertain: no details given on blinding, beyond statement to the effect | Yes: Attrition <80% for all arms; all available data used in analysis | Yes | Yes: pain scales were self-report; also used neurocognitive testing | Low
Wilsey, 2016 ^46^ Spinal cord injury | Yes: used a Web-based random number-generating program…to determine the sequence of administration. | Yes: The allocation schedule was maintained by a research pharmacist and concealed from other study personnel. | Yes: Placebo cannabis was derived from whole plant material with extraction of delta 9-THC. | Unclear: Attrition with reasons reported by group, method for handling missing data was not described. | Yes: Protocol available and all outcomes mentioned appear to be reported | No power calculation reported, but since a significant difference was found between interventions, this is unlikely to have introduced significant bias | Low
Zajicek, 2003 ^53^ MS | Yes: The coordinating center allocated the patient a trial number and then forwarded relevant details to the central trial pharmacy, where randomization took place, using a dedicated standalone computer. | Yes: Throughout the study, the list of treatment allocation codes was kept at the central trial pharmacy, located separately from the coordinating office. | No: most in the active treatment group guessed correctly that they were on active treatment; potential bias despite that placebo group was effectively blinded. | Yes | Yes | Patients selected for spasticity, not pain. Power calculation based on projected effects on spasticity. Baseline pain scores not reported, only whether improved, unchanged, or deteriorated. Unclear whether pain levels were high or low to begin with. | High
Zajicek, 2012 ^54^ MS | Yes: Computer generated permuted block randomization | Yes | Yes: Matched placebo capsules. | Yes | Yes | Yes | Low

Trials Assessing the Risk of Psychotic Symptoms with Cannabis Use – Risk of Bias (ROB) Assessment

Criteria | Englund 2013^91^ | Kaufmann 2010^89^
Sequence generation | Unclear - methods not described | Unclear - methods not described
Allocation concealment | Unclear - methods not described | Unclear - methods not described
Blinding | Yes - double blind, randomly allocated | Unclear - double blind. No details provided.
Incomplete outcome data | NA - all participants completed study | No - One participant developed acute psychotic symptoms and was not included in the statistical analysis, but was qualitatively described.
Selective outcome reporting | Yes - All relevant outcomes appear to be reported | Yes - appear to report all outcomes.
Other sources of bias | Yes - no major issues identified aside from lack of clarity around the methods used for sequence generation and allocation. | No - small sample/under powered.
Overall assessment of potential for bias | Low - despite lack of clarity about sequence generation and allocation concealment. | Moderate - due to lack of clarity about sequence generation and allocation concealment and small sample size.

Quality Assessment Criteria for Observational Studies, Based on the Newcastle-Ottawa Scale^21^

Representativeness of the exposed cohort Enter 0 or 1: 1 = truly representative of the average patient in the community 1 = somewhat representative of the average patient in the community 0 = selected group of users (eg, nurses, volunteers) 0 = no description of the derivation of the cohort
Selection of the non-exposed cohort Enter 0 or 1: 1 = drawn from the same community as the exposed cohort 0 = drawn from a different source 0 = no description of the derivation of the non-exposed cohort
Ascertainment of exposure Enter 0 or 1: 1 = biological test (eg, blood/urine) 1 = structured interview 1 = written self-report that characterizes dose (current or cumulative) 0 = written self-report without quantification of exposure 0 = no description
Precision of Exposure Dose Ascertainment Enter 0 or 1: 1 = amount and time 0 = no information about amount and time
Ascertainment of exposure done prospectively or retrospectively Enter 0 or 1: 1 = Prospectively 0 = Retrospectively
Demonstration that outcome of interest was not present at start of study, OR baseline assessment Enter 0 or 1: 1= yes 0 = no
Adjustment for confounding (rendering comparability of cohorts on the basis of the design or analysis) Add points: Minimum 0, Maximum 2 1 = study accounts/controls for other substance use 1 = study controls for any additional factor (mental health comorbidity; medication use; severity of PTSD; mental health comorbidity and treatment; socioeconomic status) 0 = no adjustment for potential confounders
Assessment of outcome Enter 0 or 1: 1 = objective measure 1 = validated self-report measures 0 = no information or non-validated measures
Was follow-up long enough for outcomes to occur? Enter 0 or 1: 1 = yes (need to define adequate follow-up period for outcome of interest) 0 = no
Adequacy of follow-up of cohorts Enter 0 or 1: 1 = complete follow-up; all subjects accounted for. 1 = subjects lost to follow-up unlikely to introduce bias; small number (less than 20 %) lost, or description was provided of those lost. 0 = follow-up rate < 80% and no description of those lost. 0 = no statement

Observational Studies in Patients with Chronic Pain – Risk of Bias (ROB) Assessment

Criteria | Ware 2015^31^ | Storr 2014^32^ | Fiz 2011^34^
Representativeness of the exposed cohort | 1 - included patients with non-cancer pain but had to be moderate/severe and refractory | 1 - exposed cohort was equal for males and females although IBS impacts females at a slightly higher base rate | 1 - somewhat; these are treatment resistant patients in particular
Selection of the non-exposed cohort | 1 - all drawn from same clinical centers | 1 - drawn from same source | 0 - 2 of the recruitment sites were the same (FM associations and outpatient rheumatology) but cannabis group also recruited from cannabis association.
Ascertainment of exposure | 1 - pharmacy dispensed and recorded use | 0 - self-report; only method of administration (ie, smoking) recorded | 0 - information reported about duration of cannabis use (ie, 1 year) and administration modality, but no info provided about dose or cannabinoid concentration.
Precision of Exposure Dose Ascertainment | 1 - dosing described | 0 - no dosing information provided | 0 - method of administration varied among users (smoking 54%; oral 46%; combined 43%), duration and frequency of use varied among users. Dosage varied among users (“1-2 cigarettes each time when smoked or 1 spoonful each time when eating”). No info on THC/CBD content given. 39% used daily, 18% used 2-5 days per week.
Ascertainment of exposure done prospectively or retrospectively | 1 - prospectively | 0 - cross-sectional so ascertainment based on one timepoint | 0 - exposure groups established by use status
Demonstration that outcome of interest was not present at start of study, OR baseline assessment | 1 - all results compared to baseline | 0 - no baseline | 1 - baseline data gathered 2 hours prior to exposure
Adjustment for confounding | 2 - cohort significantly different on age, gender, disability status, tobacco status, past cannabis use, drug abuse screening, average pain intensity (cannabis users higher) and medications – however, these group differences were controlled for in the inferential statistics. | 2 - study adjusts for demographic variables, tobacco smoking status, time since diagnosis, and biological use | 0 - no adjustments made
Assessment of outcome | 1 - objective/validated measures used | 0 - surgical history gleaned from medical chart (only measure of utilization provided) no other validated measures reported for our PICOTS. Side effects and perceived utility of cannabis for treatment of IBD symptoms all subjective and only descriptive data is provided for users. | 1 - validated self-report measures for outcomes (eg, VAS, SF-36)
Was follow-up long enough for outcomes to occur? | 1 - (12 months follow-up) | 0 - no follow-up | 0 - difficult to ascertain sustainability of outcomes, only 2 hours of follow-up
Adequacy of follow-up of cohorts | 1 - > 20% loss to follow-up in the cannabis group but all subjects are accounted for and all subjects included in the primary safety analysis | 0 | 1 - appears to be complete follow-up
Comments on study quality | Low ROB - there are some concerns as noted below but what is measurable by scale appears to be properly done - Study's primary outcomes were adverse events, other outcomes were secondary; Study notes that protocol changes were made but no details provided; Study did not recruit pre-specified sample size for power; Multiple adjustments and subgroup analyses were undertaken; Also, strange that inclusion into cannabis group relied on use of cannabis but there are persons included there who are cannabis naïve and who were ex-users; baseline demographics/ population details differed by group, though adjustments made in analyses...the majority (66%) of the cannabis users were experienced, making the generalizability to cannabis-naïve users difficult, and differences in the follow-up times between the control and exposure group may have artificially inflated the number of AEs reported by cannabis users. | High ROB - dosing information was not provided or consistent for users, data collection only at one time point so no f/u data provided. Minimal outcomes of interest. | High ROB - dosing information was not provided or consistent for users, participants gathered from different sources introducing selection bias; groups were established by exposure status and those using cannabis are likely to differ from others not using cannabis (although baseline characteristics are not different per study authors and this is the only way to conduct a cohort study), also concern that there were no adjustments made for other medications used, small sample size, use of self-reported measures, very limited follow-up with a pre-, post-design rather than between group comparison for primary outcome
Notes on Applicability | Patients had treatment moderate/severe, refractory chronic pain but otherwise applicable, especially since drawn from clinical centers | | Patients had treatment resistant FM

Observational Studies in Patients with PTSD – Risk of Bias (ROB) Assessment

Criteria | Wilkinson 2015^60^ | Johnson 2016^61^
Representativeness of the exposed cohort | 1 | 1
Selection of the non-exposed cohort | 1 | 1
Ascertainment of exposure | 0 (self-report) | 0 (self-report)
Precision of Exposure Dose Ascertainment | 0 (not specific) | 0 (not specific)
Ascertainment of exposure done prospectively or retrospectively | 1 | 0
Demonstration that outcome of interest was not present at start of study, OR baseline assessment | 1 | n/a
Adjustment for confounding | 1 (included all assessed confounders related to cannabis use) | 0
Assessment of outcome | 1 (validated self-report measures) | 1 (validated self-report measures)
Was follow-up long enough for outcomes to occur? | 1 (4 months) | n/a
Adequacy of follow-up of cohorts | 1 | n/a
Comments on study quality | Medium ROB | High ROB
Notes on Applicability | VA population with PTSD | VA population with PTSD

Observational Studies of Medical Harms Associated with Cannabis Use – Risk of Bias (ROB) Assessment

Criteria | Pletcher 2012^70^ | Hancox 2010^69^ | Mittleman 2001^73^ | Frost 2013^72^ | Carvalho 2015^74^
Representativeness of the exposed cohort | 1 - truly representative Community based study in 4 cities representing different parts of country, ethnically diverse group. | 1 - somewhat representative (birth cohort, but for that reason does not represent older patients in the community) | 1 - somewhat representative of MI patients - not community, but most MI patients would get cared for in hospital and this was multisite hospital study | 1 - somewhat representative of MI patients - not community, but most MI patients would get cared for in hospital and this was multisite hospital study | 1 - in half the studies, these were hospital patients, half the studies used cancer registry data
Selection of the non-exposed cohort | 1 - drawn from same community | 1 - same community | 1 - self-control | 1 - same community | 1 - most studies found general population controls (eg, electoral rolls, random digit dialing)
Ascertainment of exposure | 1 - structured interview | 1 - interview | 0 - risk of recall bias, not clear how accurate recalled pattern of use over prior year was - since this formed basis for control (expected frequency of hourly use) there is some potential for bias. | 1 - interview | 1 - most studies used structured interview
Precision of Exposure Dose Ascertainment | 1 - amount and time | 1 - amount and time | 0 - not enough information about amount and time | 0 - time only, and only at baseline | 1 - most gathered information about amount and time
Ascertainment of exposure done prospectively or retrospectively | 1 - prospectively | 1 - prospectively | 0 - retrospectively | 0 - retrospectively | 0 - retrospectively
Demonstration that outcome of interest was not present at start of study, OR baseline assessment | 1 - yes - PFTs were longitudinally collected - baseline PFT data were available and outcomes were reported as change from baseline | 1 - yes, serial PFT measures, and they adjusted for spirometry at age 15 | n/a | 1 - yes (inception cohort) | 0 - no
Adjustment for confounding | 1 - for PFT outcomes, most important covariate is tobacco exposure along with gender, age, race all of which were well accounted for. | 1 - accounts for tobacco exposure, age, gender which are probably most relevant for the PFT outcomes - did not account for race, SES, second hand smoke exposure, etc | 0 - not clear that they account for tobacco use in hour prior to MI | 1 - propensity score matching - adjusted for tobacco, other substance use, SES other factors | 1 - most studies adjusted for tobacco use and alcohol use
Assessment of outcome | 1 - PFTs, objective measure | 1 - PFTs | 1- objective assessment of MI outcome | 1 - national death index | 1 - only included studies of patients with definitive HNC
Was follow-up long enough for outcomes to occur? | 1 - yes | 1 - yes | n/a | 1 - yes, partly - the exposed group was younger and the number of mortality events therefore relatively small, but 18 year f/u | n/a
Adequacy of follow-up of cohorts | 1 - data from 98% of participants, 95% of all visits had complete data | 1 - data from 96% of original cohort at 32 years | n/a | 1 - national death index | n/a
Comments on study quality | Low ROB. Well-conducted, prospective cohort study. Should be one of the better sources of data for this outcome. | Low ROB. Well-conducted, prospective cohort study. Similar to Pletcher study, but did not have data on linear trends. | High ROB. Case-crossover study with several potential sources of bias including recall bias, small # patients with exposure of interest, and lack of clarity re: accounting for tobacco use. | High ROB. Information on exposure (both cannabis and tobacco) only available at baseline interview. Assess long-term mortality, but no information on total use over the period of follow-up, making it difficult to assess relationship between exposure and outcome. Moreover, cannabis users were different than non-users - confounders were adjusted for, but strong possibility of residual confounding. | Medium ROB. Ascertainment of exposure is necessarily limited by retrospective nature and issues of recall bias.
Notes on Applicability | Applicable to younger populations (< 30) | Applicable to younger populations | Most cannabis users were male | Most cannabis users were male, younger than nonusers | Very wide range of ever cannabis use - some of the studies with very low rates of use may not be applicable, but the consistency of results across different study populations is reassuring.

Medical Harms Observational Studies – Risk of Bias (ROB), Continued

Criteria | Zhang 2015^75^ | Callaghan 2013^76^ | Gurney 2015^77^ | Chacko 2006^78^
Representativeness of the exposed cohort | 1 - international, mix of hospital-based and community studies | 1 - nearly all (98%) 18-20 year old males | 1 - cancer registry cases with community-based controls | 1 - representative of transitional cell ca population, at least in VA
Selection of the non-exposed cohort | 1 - all drew controls either from same hospital/clinic, or the community | 1 - drawn from same population | 1 - drawn from same population (random general population in 2 studies and friends of cases in one study which is a potential source of selection bias) | 0 - drawn from urology clinic, presenting for different reason - not representative of community
Ascertainment of exposure | 1 - written self-report with information on duration and frequency | 0 - self-report without adequate quantification | 0 - interview in 2 studies and written self-report with quantification in other, but not clear that interviewers were blinded to case/control status of participant | 1 - written self-report with information on duration and frequency
Precision of Exposure Dose Ascertainment | 1 - amount and time | 0 - minimal information about exposure over time | 1 - amount and time | 1 - amount and time
Ascertainment of exposure done prospectively or retrospectively | 0 - retrospectively | 0 - retrospectively, and only at time of conscription | 0 - retrospectively | 0 - retrospectively
Demonstration that outcome of interest was not present at start of study, OR baseline assessment | 1 - performed additional analyses excluding patients who had used within 2 years of cancer diagnosis (to evaluate possibility of reverse causality) | 0 - no, but very unlikely that outcome was present in young age group | 1 - (case-control) | n/a
Adjustment for confounding | 1 - adjusted for tobacco use and some other sociodemographic factors | 0 - adjusted for multiple factors, but did not have a way of quantifying tobacco exposure after conscription which is likely to have been heaviest amongst those with heavier cannabis use | 1 - adjusted for major confounders relevant to disease (including cryptorchidism), but one study did not adjust for alcohol or tobacco use (but was also the smallest of the studies) | 0 - important confounders considered, but they did not report adequately the adjusted analyses
Assessment of outcome | 1 - only histologically confirmed lung cancer | 1 - based on national medical records, claims - fair validation | 1 - histologically confirmed cancers | 1 - confirmed cancers
Was follow-up long enough for outcomes to occur? | n/a | 1 - yes | n/a | n/a
Adequacy of follow-up of cohorts | n/a | 1 - 1.9% lost to f/u due to emigration | n/a | n/a
Comments on study quality | Medium ROB - ascertainment of exposure is necessarily limited by retrospective nature and issues of recall bias. | High ROB - biggest issue was that the main exposure and main confounder (tobacco use) were only determined at time of conscription. High risk of residual confounding due to ongoing tobacco exposure for finding of heavy cannabis use association with lung cancer. | High ROB - the meta-analysis itself was well done, but there were methodologic deficiencies in all 3 included studies. The smallest study did not control for important confounders such as tobacco. Low response rates among controls or cases in the 2 bigger studies. There was a potential for ascertainment bias, and recall bias is also an issue. Use of friends as controls in one study is a potential source of bias. The largest and methodologically strongest study showed results consistent with overall findings, direction of effect was consistent across studies, there was a dose-response relationship, and the authors do highlight some biologic plausibility to findings. | High ROB - small study, 2 VA sites, very little information on adjusted analyses, control group were symptomatic patients in urology clinic so not representative of community, reverse causality a real concern (ie, cancer patients may have been using cannabis to palliate symptoms - no information on timing of use and diagnosis), recall bias
Notes on Applicability | Variety of settings, included squamous cell and adenocarcinoma patients but few patients with other types of lung cancer. | -- | -- | VA only - 2 sites. One of the sites located in a town with prominent textile industry (and, thus, dye exposure). Small number of patients.

Observational Studies of Adverse Mental Health Effects Associated with Cannabis Use – Risk of Bias (ROB) Assessment

Criteria | Di Forti 2009^92^ | Dominguez 2010^87^ | Kuepper 2011^86^ | Mason 2008^90^ | Rossler 2011^88^ | van Nierop 2013^137^
Representativeness of the exposed cohort | 1 - first episode psychosis (presenting to the hospital) | 1 - representative population study. | 1 - representative population study. | 0 - No information about the population from which the sample was recruited. Recreational cannabis smokers who used cannabis at least once a month. No personal history of diagnosed mental illness. Lifetime drug usage of other illicit drugs in the cannabis group commonly included amphetamines, benzodiazepines, cocaine, ketamine, LSD, and heroin. | 1 - representative population based sample. Males identified from a military screening test, and females from an electoral roster. | 1 - somewhat representative (siblings of individuals with psychotic disorders and healthy controls in the same geographical areas)
Selection of the non-exposed cohort | 0 - No description of source. Control group was individuals with no psychotic episodes. | 1 - same population | 1 - same population | 0 - No description of source | 1 - same population | 1 - same community
Ascertainment of exposure | 1 - Cannabis Experience Questionnaire | 1 - Munich composite international diagnostic interview (DIA-X/M-CIDI) | 1 - Munich composite international diagnostic interview (DIA-X/M-CIDI) | 1 - self-report and urinalysis | 1 - Structured Psychopathological Interview and Rating of the Social Consequences of Psychological Disturbances for Epidemiology (SPIKE) | 1 - urinalysis and CIDI
Precision of Exposure Dose Ascertainment | 1 - Assessed type and frequency, as well as potency | 0 - > or < 5 times since last exposure | 0 - > or < 5 times since last exposure | 0.5 - Participants contacted researchers when they were using cannabis recreationally. The study team went to meet them for testing. Dose not ascertained. | 1 - frequency of use | 0.5 - used interviews to determine lifetime use and urinalysis to determine current use. No information re: dose, frequency, etc
Ascertainment of exposure done prospectively or retrospectively | 0 - retrospectively | 0 - retrospectively | 0 - retrospectively | 1 - prospectively | 0 - retrospectively | 0 - retrospectively
Demonstration that outcome of interest was not present at start of study, OR baseline assessment | 1 - first psychotic episode | 0 - not excluded | 0 - not excluded | 0 - not excluded, and no baseline assessment. | 1 - although clinical diagnoses of psychotic disorders were not assessed with the SPIKE at baseline through 1999, two-thirds of the sample were at “high risk” for subclinical psychosis symptoms based on Symptom Checklist 90—Revised (SCL-90-R) scores. | 1 - healthy siblings of individuals with a psychotic disorder (high risk) and healthy controls.
Adjustment for confounding | 2 - adjusted for age, gender, ethnicity, other stimulant use, education, and employment status. | 1 - controls for depression but not other substance use | 2 - Adjusted for age at baseline, sex, baseline SES, use of other drugs at baseline and T2, trauma before the age of 14 as assessed at baseline, and urban/rural environment. | 1 - performed sensitivity analysis for other drug/alcohol use | 2 - adjusted for sex, familial background, socio- economic status, family history of mental disorders, other family problems, and school problems, and used step wise multivariate analysis with each substance entered individually. | 0 - adjusts only for age, sex, high-risk sibling status
Assessment of outcome | 1 - hospital admission | 1 - Munich composite international diagnostic interview (DIA-X/M-CIDI) | 1 - Munich composite international diagnostic interview (DIA-X/M-CIDI) | 0 - Psychotomimetic States Inventory (PSI) - the study is a validation study. | 1 - SPIKE and SCL-90-R | 1 - Community Assessment of Psychic Experience (CAPE)
Was follow-up long enough for outcomes to occur? | NA | 1 - Mean T1 1.6, T2 3.5, and T3 8.4 years (range=7.3-10.5) | 1 - Mean T1 1.6, T2 3.5, and T3 8.4 years (range=7.3-10.5) | 1 - interested in acute symptoms. Assessed at time of exposure, then 3 to 4 days later. | 1 - 30 years | 0 - Mean 3.3 years
Adequacy of follow-up of cohorts | NA | 0 - 84% at T2 and 73% at T3. No description provided. | 0 - 84% at T2 and 73% at T3. No description provided. | NA - no follow-up other than 3-4 days post use. | 1 - 57% assessed at 30 year follow-up. Description of lost provided. | 1 - 78% assessed at follow-up. Description of participants lost provided.
Comments on study quality | Low ROB study despite lack of detail on ascertainment of control group. Nicely conducted retrospective study. | Moderate ROB study. Included participants with negative/disorganized symptoms at baseline. | Moderate ROB study. Included participants with negative/disorganized symptoms at baseline. | High ROB study. No information about the source of the exposed or non-exposed sample. Exposed sample used drugs in addition to cannabis, and there was no baseline assessment. No information about dose ascertained. | Low ROB study. Well-conducted, good description of follow-up and loss to follow-up, description of methods, etc | High ROB due to lack of controlling for important confounders, short follow-up