# APPENDIX B STUDY SELECTION

## Inclusion Codes, Code Definitions, and Criteria

***Please note: Important background/discussion papers may be coded “B” followed by an exclusion code, with notes or key words. For example: B–X2, pearl for references

1. Does the intervention or exposure consist of cannabis preparations including marijuana, hashish, tincture, hashish oil, infusion, and plant extract (eg, Sativex)?
  - No → STOP. Code X1 (Not relevant to topic)
  - Yes → Proceed to 2.
2. Is the article any of the following study designs or publication types:
  - Non-systematic or narrative review
  - Opinion/editorial
  - Cross-sectional study
  - Individual case report
  - No → Proceed to 3.
  - Yes → STOP. Code X2 (Excluded study design or publication type)
3. Does the population include adults with chronic pain or PTSD?
  - No → Go to 10.
  - Yes: Chronic pain → Go to 20.
  - Yes: PTSD → Go to 30.

X4 = lab/blood/imaging findings

X5 = superseded by previous high-quality systematic review

[underlined: Questions 10-13 deal with] KQ3 [underlined: (harms) in the general population]

10 Are the majority of the study subjects either of the following:
  - Younger than age 18
  - Adults diagnosed with a psychotic disorder (eg, schizophrenia)
  - No → Proceed to 11.
  - Yes → STOP. Code X10 (Excluded pop for KQ3)
11 Does the study report any of the following harms:
  - Fungal infections
  - Cannabinoid hyperemesis syndrome
  - Other emerging harms (potential example: sudden onset of violent behaviors)
  - No → Proceed to 12.
  - Yes → Code I-11 (Gen pop, rare harms, KQ3)
    [underlined: Proceed] with items 12 and 13. Add Code I-13 if applicable.
12 Does the study report any of the following harms:
  - Psychotic symptoms
  - Cardiovascular events
  - Pulmonary/FEV1 outcomes
  - Infectious disease complications
  - Traffic collisions
  - Mortality
  - No → STOP. Code X12 (Gen pop, no harms of interest reported)
  - Yes → Proceed to 13.
13 Does the study design include a control group? The control group should differ from the primary group in dose or duration of cannabis use (including no use). However, a study comparing onset of cannabis use during adolescence vs adulthood would be excluded.
  - No → STOP. Code X13 (Gen pop, no control group for specified harms)
  - Yes → STOP. Code I-13 (Gen pop, has control group for specified harms)

[underlined: Questions 20-22 deal with chronic pain]

20 Do the study outcomes include either of the following:
  - Cannabis use disorder
  - Withdrawal symptoms
  - No → Proceed to 21.
  - Yes → Code I-20 (Pain pop, no controls needed for specified harms)
    [underlined: Proceed] with items 21 and 22. Add Code I-22 if applicable.
21 Does the study report any of the following outcomes? The list below includes effectiveness outcomes and specific adverse effects of interest:
  - Validated measures of pain intensity and pain-related function (including spasticity)
  - Validated measures of pain-related outcomes (mood, depression, anxiety)
  - Validated measures of sleep quality
  - Validated measures of quality of life
  - Utilization of health services
  - Reduction in opioid use or dosage
  - Social functioning/disability
  - Other substance use/substance use disorder
  - Mental health symptoms including depression, anxiety, etc (not psychotic symptoms)
  - Cognitive effects (eg, IQ, SLUMS, or measures of memory, processing speed, attention, learning, executive function, etc)
  - Employment
  - Weight gain
  - Diversion
  - Insomnia
  - No → STOP. Code X21 (Pain pop, no outcomes of interest)
  - Yes → Proceed to 22.
22 Is the study design a controlled clinical trial, case-control, or cohort study with a comparison group?
  - No → STOP. Code X22 (Pain pop, excluded study design)
  - Yes → STOP. Code I-22 (Pain pop, addresses KQ1 and/or KQ3)

[underlined: Questions 30-32 deal with PTSD]

30 Do the study outcomes include either of the following:
  - Cannabis use disorder
  - Withdrawal symptoms
  - No → Proceed to 31.
  - Yes → Code I-30 (PTSD, no controls needed for specified harms)
    Proceed with items 31 and 32. Add Code I-32 if applicable.
31 Does the study report any of the following outcomes? The list below includes effectiveness outcomes and specific adverse effects of interest:
  - Validated PTSD clinical interviews and symptom inventories, such as:
    ❖ Clinician Administered PTSD Scale (CAPS)
    ❖ PSTD Checklist (PCL)
    ❖ PTSD Symptom Scale (PSS)
    ❖ Posttraumatic Diagnostic Scale (PDS).
  - Validated measures of mental health symptoms commonly associated with PTSD (mood, depression, anxiety)
  - Validated measures of sleep quality
  - Validated measures of quality of life
  - Utilization of health services
  - Reduction in benzodiazepine use or dosage
  - Social functioning/disability
  - Other substance use/substance use disorder
  - Mental health symptoms including depression, anxiety, etc (not psychotic symptoms)
  - Cognitive effects (eg, IQ, SLUMS or measures of memory, processing speed, attention, learning, executive function)
  - Employment
  - Weight gain
  - Diversion
  - Insomnia
  - No → STOP. Code X31 (PTSD, no outcomes of interest)
  - Yes → Proceed to 32.
32 Is the study design a controlled clinical trial, case-control, or cohort study with a comparison group?
  - No → STOP. Code X32 (PTSD, excluded study design)
  - Yes → STOP. Code I-32 (PTSD, addresses KQ2 and/or KQ3)