# APPENDIX A SEARCH STRATEGIES

## Databases/Websites

- Ovid Medline
- PubMed (non-Medline materials)
- Elsevier EMBASE
- Ovid PsycINFO
- PILOTS Database (PTSD search only)
- EBM Reviews (CDSR, DARE, HTA, Cochrane CENTRAL, etc)
- Conference Papers Index
- Clinicaltrials.gov
- International Clinical Trials Registry Platform (WHO ICTRP)
- ISRCTN
- NIH Reporter
- AHRQ Gold
- American Cancer Society Database of Studies

## Search Strategies

### Ovid MEDLINE(R) and Ovid OLDMEDLINE(R) 1946 to December Week 5 2015, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations January 11, 2016

Date Searched: Tuesday January 12, 2016

# | Searches | Results
1 | medical marijuana/ or cannabis/ or marijuana smoking/ or exp Cannabinoids/ or Cannabaceae/ | 18682
2 | (cannabis or canabis or cannabinoid* or cannabidiol* or CBD or cannabacae or marijuana or marihuana or hashish or hash or ganja or ganjah or hemp or bhang or charas or THC or tetrahydrocannabinol* or tetra-hydrocannabinol* or 9?tetrahydrocannabinol* or DELTA?9?-tetrahydrocannabinol*).tw. | 38570
3 | 1 or 2 | 41269
4 | pain/ or acute pain/ or breakthrough pain/ or mastodynia/ or exp musculoskeletal pain/ or exp back pain/ or chronic pain/ or facial pain/ or headache/ or metatarsalgia/ or neck pain/ or exp neuralgia/ or exp nociceptive pain/ or pain, intractable/ or pain, referred/ | 205083
5 | (pain or pains or painful* or migraine* or headache* or neuropath* or neuralgia* or arthriti* or fibromyalg*).tw. | 770253
6 | 4 or 5 | 823437
7 | 3 and 6 | 2868
8 | 7 and (humans/ not animals/) | 1331
9 | 7 not (humans/ or animals/) | 312
10 | 8 or 9 | 1643
11 | limit 10 to (case reports or comment or editorial or letter or news) | 293
12 | cross-section*.tw. | 243912
13 | 10 not (11 or 12) | 1313
14 | limit 13 to english language | 1211
15 | stress disorders, traumatic/ or combat disorders/ or stress disorders, post-traumatic/ | 26019
16 | (PTSD or post-traumatic stress or posttraumatic stress).ti,ab. | 23732
17 | 15 or 16 | 32767
18 | 3 and 17 | 210
19 | 18 and (humans/ not animals/) | 131
20 | 18 not (humans/ or animals/) | 31
21 | 19 or 20 | 162
22 | limit 21 to (case reports or comment or editorial or letter or news) | 9
23 | cross-section*.tw. | 243912
24 | 21 not (22 or 23) | 140
25 | limit 24 to english language | 132
26 | medical marijuana/ or cannabis/ or marijuana smoking/ or marijuana abuse/ or exp Cannabinoids/ or Cannabaceae/ | 22185
27 | (cannabis* or canabis* or cannabinoid* or cannabidiol* or CBD or cannabacae or marijuana* or marihuana* or hashish* or hash or ganja or ganjah or hemp or bhang or charas or THC or tetrahydrocannabinol* or tetra-hydrocannabinol* or 9?tetrahydrocannabinol* or DELTA?9?-tetrahydrocannabinol*).tw. | 38598
28 | 26 or 27 | 41948
29 | (ae or co or de).fs. | 5311331
30 | (harm or harms or harmful or safe or safety or side effect* or undesirable effect* or treatment emergent or tolerability or toxic* or adrs or damag* or impair* or disorder* or abuse* or addict* or withdrawal* or (adverse adj2 (effect or effects or reaction or reactions or event or events or outcome or outcomes))).tw. | 3065069
31 | 29 or 30 | 7263273
32 | 28 and 31 | 25510
33 | limit 32 to (meta analysis or systematic reviews) | 422
34 | 32 not 33 | 25088
35 | 34 and (humans/ not animals/) | 13847
36 | 34 not (humans/ or animals/) | 1758
37 | 35 or 36 | 15605
38 | limit 37 to (“all adult (19 plus years)” or “young adult (19 to 24 years)” or “adult (19 to 44 years)” or “young adult and adult (19-24 and 19-44)” or “middle age (45 to 64 years)” or “middle aged (45 plus years)” or “all aged (65 and over)” or “aged (80 and over)”) | 8086
39 | limit 38 to (case reports or comment or editorial or letter or news) | 1030
40 | cross-section*.tw. | 243912
41 | 38 not (39 or 40) | 6701
42 | limit 41 to english language | 6238

### PubMed

Date searched: Friday May 6, 2016

# | Searches | Results
#10 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#7 OR #8 OR #9) | 444 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#9 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ((((((cannabis*[tiab] OR canabis*[tiab] OR cannabinoid*[tiab] OR cannabidiol*[tiab] OR CBD[tiab] OR cannabacae[tiab] OR marijuana*[tiab] OR marihuana*[tiab] OR hashish*[tiab] OR hash[tiab] OR ganja[tiab] OR ganjah[tiab] OR hemp[tiab] OR bhang[tiab] OR charas[tiab] OR THC[tiab] OR tetrahydrocannabinol*[tiab] OR tetra-hydrocannabinol*[tiab] OR 9?tetrahydrocannabinol*[tiab] OR DELTA?9?-tetrahydrocannabinol*[tiab])))) AND (((harm[tiab] OR harms[tiab] OR harmful[tiab] OR safe[tiab] OR safety[tiab] OR side effect*[tiab] OR undesirable effect*[tiab] OR treatment emergent[tiab] OR tolerability[tiab] OR toxic*[tiab] OR adrs[tiab] OR damag*[tiab] OR impair*[tiab] OR disorder*[tiab] OR abuse*[tiab] OR addict*[tiab] OR withdrawal*[tiab] OR adverse effect[tiab] OR adverse effects[tiab] OR adverse reaction[tiab] OR adverse reactions[tiab] OR adverse event[tiab] OR adverse events[tiab] OR adverse outcome[tiab] OR adverse outcomes[tiab])))) AND (((pubmednotmedline[sb] OR inprocess[sb] OR [publisher[sb]))))) AND (((((meta-review*[tiab] OR meta-epidemiolog*[tiab] OR metaepidemiolog*[tiab] OR horizon scan*[tiab] OR systematic* review*[tiab] OR systematic effectiveness review*[tiab] OR comparative effectiveness review*[tiab] OR evidence review*[tiab] OR landscape review*[tiab] OR quantitative review*[tiab] OR qualitative review*or integrative review*or mixed-method* review*or mixed method* review*[tiab] OR research review*or scoping review*[tiab] OR umbrella review*or review of review*[tiab] OR updat* review*[tiab] OR cochrane review*or campbell review*[tiab])) OR (research* aggregat*[tiab] OR evidence aggregat*[tiab] OR evidence map*[tiab] OR evidence brief*[tiab] OR evidence summar*[tiab] OR rapid review*or mini* review*or pragmatic review*or targeted review*or focused review*or brief review*or short review*[tiab])) OR (meta-analy*[tiab] OR metaanaly*[tiab] OR meta-meta-analy*[tiab] OR evidence synthes*[tiab] OR knowledge synthes*[tiab] OR quantitative synthes*[tiab] OR research synthes*[tiab] OR pooled analy*[tiab] OR indirect* comparison*[tiab] OR mixed* comparison*[tiab])) OR (HTA[tiab] OR health technology assessment*[tiab] OR mini-HTA*[tiab] OR relative effectiveness assessment*[tiab])) | 16 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#8 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (((((cannabis*[tiab] OR canabis*[tiab] OR cannabinoid*[tiab] OR cannabidiol*[tiab] OR CBD[tiab] OR cannabacae[tiab] OR marijuana*[tiab] OR marihuana*[tiab] OR hashish*[tiab] OR hash[tiab] OR ganja[tiab] OR ganjah[tiab] OR hemp[tiab] OR bhang[tiab] OR charas[tiab] OR THC[tiab] OR tetrahydrocannabinol*[tiab] OR tetra-hydrocannabinol*[tiab] OR 9?tetrahydrocannabinol*[tiab] OR DELTA?9?-tetrahydrocannabinol*[tiab])))) AND (((PTSD[tiab] OR post-traumatic stress[tiab] OR posttraumatic stress[tiab])))) AND (((pubmednotmedline[sb] OR inprocess[sb] OR [publisher[sb])))) | 39 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#7 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (((((cannabis*[tiab] OR canabis*[tiab] OR cannabinoid*[tiab] OR cannabidiol*[tiab] OR CBD[tiab] OR cannabacae[tiab] OR marijuana*[tiab] OR marihuana*[tiab] OR hashish*[tiab] OR hash[tiab] OR ganja[tiab] OR ganjah[tiab] OR hemp[tiab] OR bhang[tiab] OR charas[tiab] OR THC[tiab] OR tetrahydrocannabinol*[tiab] OR tetra-hydrocannabinol*[tiab] OR 9?tetrahydrocannabinol*[tiab] OR DELTA?9?-tetrahydrocannabinol*[tiab])))) AND (((pain[tiab] OR pains[tiab] OR painful*[tiab] OR migraine*[tiab] OR headache*[tiab] OR neuropath*[tiab] OR neuralgia*[tiab] OR arthriti*[tiab] OR fibromyalg*[tiab])))) AND (((pubmednotmedline[sb] OR inprocess[sb] OR [publisher[sb])))) | 392 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#6 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ((meta-review*[tiab] OR meta-epidemiolog*[tiab] OR metaepidemiolog*[tiab] OR horizon scan*[tiab] OR systematic* review*[tiab] OR systematic effectiveness review*[tiab] OR comparative effectiveness review*[tiab] OR evidence review*[tiab] OR landscape review*[tiab] OR quantitative review*[tiab] OR qualitative review*or integrative review*or mixed-method* review*or mixed method* review*[tiab] OR research review*or scoping review*[tiab] OR umbrella review*or review of review*[tiab] OR updat* review*[tiab] OR cochrane review*or campbell review*[tiab])) OR (research* aggregat*[tiab] OR evidence aggregat*[tiab] OR evidence map*[tiab] OR evidence brief*[tiab] OR evidence summar*[tiab] OR rapid review*or mini* review*or pragmatic review*or targeted review*or focused review*or brief review*or short review*[tiab]) OR (meta-analy*[tiab] OR metaanaly*[tiab] OR meta-meta-analy*[tiab] OR evidence synthes*[tiab] OR knowledge synthes*[tiab] OR quantitative synthes*[tiab] OR research synthes*[tiab] OR pooled analy*[tiab] OR indirect* comparison*[tiab] OR mixed* comparison*[tiab]) OR (HTA[tiab] OR health technology assessment*[tiab] OR mini-HTA*[tiab] OR relative effectiveness assessment*[tiab])) | 78086 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#5 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (pubmednotmedline[sb] OR inprocess[sb] OR publisher[sb]) | 2833028 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#4 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (harm[tiab] OR harms[tiab] OR harmful[tiab] OR safe[tiab] OR safety[tiab] OR side effect*[tiab] OR undesirable effect*[tiab] OR treatment emergent[tiab] OR tolerability[tiab] OR toxic*[tiab] OR adrs[tiab] OR damag*[tiab] OR impair*[tiab] OR disorder*[tiab] OR abuse*[tiab] OR addict*[tiab] OR withdrawal*[tiab] OR adverse effect[tiab] OR adverse effects[tiab] OR adverse reaction[tiab] OR adverse reactions[tiab] OR adverse event[tiab] OR adverse events[tiab] OR adverse outcome[tiab] OR adverse outcomes[tiab]) | 3137250 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#3 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (PTSD[tiab] OR post-traumatic stress[tiab] OR posttraumatic stress[tiab]) | 24584 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#2 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (pain[tiab] OR pains[tiab] OR painful*[tiab] OR migraine*[tiab] OR headache*[tiab] OR neuropath*[tiab] OR neuralgia*[tiab] OR arthriti*[tiab] OR fibromyalg*[tiab]) | 788713 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#1 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (cannabis*[tiab] OR canabis*[tiab] OR cannabinoid*[tiab] OR cannabidiol*[tiab] OR CBD[tiab] OR cannabacae[tiab] OR marijuana*[tiab] OR marihuana*[tiab] OR hashish*[tiab] OR hash[tiab] OR ganja[tiab] OR ganjah[tiab] OR hemp[tiab] OR bhang[tiab] OR charas[tiab] OR THC[tiab] OR tetrahydrocannabinol*[tiab] OR tetrahydrocannabinol*[tiab] OR 9?tetrahydrocannabinol*[tiab] OR DELTA?9?-tetrahydrocannabinol*[tiab]) | 39258 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)

### EMBASE.COM

Date Searched: Tuesday May 10, 2016

# | Searches | Results
#1 | ‘medical cannabis’/mj OR ‘cannabis’/mj OR ‘cannabis smoking’/mj OR ‘cannabinoid’/exp/mj OR ‘cannabaceae’/mj | 28,447
#2 | cannabis:ab,ti OR canabis:ab,ti OR cannabinoid*:ab,ti OR cannabidiol*:ab,ti OR cbd:ab,ti OR cannabacae:ab,ti OR marijuana:ab,ti OR marihuana:ab,ti OR hashish:ab,ti OR hash:ab,ti OR ganja:ab,ti OR ganjah:ab,ti OR hemp:ab,ti OR bhang:ab,ti OR charas:ab,ti OR thc:ab,ti OR tetrahydrocannabinol*:ab,ti OR ‘tetra hydrocannabinol*’:ab,ti OR ‘9 tetrahydrocannabinol*’:ab,ti OR 9tetrahydrocannabinol*:ab,ti OR ‘delta*9*tetrahydrocannabinol 11carboxylic acid’:ab,ti | 52,180
#3 | #1 OR #2 | 57,164
#4 | ‘pain’/mj OR ‘breakthrough pain’/mj OR ‘mastalgia’/mj OR ‘musculoskeletal pain’/mj OR ‘low back pain’/mj OR ‘backache’/exp/mj OR ‘chronic pain’/mj OR ‘face pain’/mj OR ‘headache and facial pain’/exp/mj OR ‘metatarsalgia’/mj OR ‘neck pain’/mj OR ‘neuralgia’/exp/mj OR ‘nociceptive pain’/mj OR ‘intractable pain’/mj OR ‘referred pain’/mj | 243,955
#5 | pain:ab,ti OR pains:ab,ti OR painful*:ab,ti OR migraine*:ab,ti OR headache*:ab,ti OR neuropath*:ab,ti OR neuralgia*:ab,ti OR arthriti*:ab,ti OR fibromyalg*:ab,ti | 1,079,039
#6 | #4 OR #5 | 1,130,556
#7 | #3 AND #6 | 4,553
#8 | #7 AND ‘human’/de NOT ‘nonhuman’/de | 2,655
#9 | #8 AND (‘editorial’/it OR ‘letter’/it OR ‘note’/it) | 80
#10 | ‘cross-section*’:ab,ti | 297,421
#11 | #8 NOT (#9 OR #10) | 2,516
#12 | #8 NOT (#9 OR #10) AND [english]/lim | 2,308
#13 | #8 NOT (#9 OR #10) AND [english]/lim AND [embase]/lim | 2,088
#14 | ‘posttraumatic stress disorder’/mj | 23,335
#15 | ptsd:ab,ti OR ‘post-traumatic stress’:ab,ti OR ‘posttraumatic stress’:ab,ti | 29,813
#16 | #14 OR #15 | 34,693
#17 | #3 AND #16 | 314
#18 | #17 AND ‘human’/de NOT ‘nonhuman’/de | 227
#19 | #18 AND ‘editorial’/it | 1
#20 | ‘cross-section*’:ab,ti | 297,421
#21 | #17 NOT (#19 OR #20) | 295
#22 | #17 NOT (#19 OR #20) AND [english]/lim | 286
#23 | #17 NOT (#19 OR #20) AND [english]/lim AND [embase]/lim | 267
#24 | ‘medical cannabis’/mj OR ‘cannabis’/mj OR ‘cannabis smoking’/mj OR ‘cannabinoid’/exp/mj OR ‘cannabaceae’/mj OR ‘cannabis addiction’/mj | 30,213
#25 | #2 OR #24 | 57,324
#26 | #25 AND (‘adverse drug reaction’/lnk OR ‘complication’/lnk OR ‘drug interaction’/lnk OR ‘drug toxicity’/lnk OR ‘side effect’/lnk) | 7,995
#27 | harm:ab,ti OR harms:ab,ti OR harmful:ab,ti OR safe:ab,ti OR safety:ab,ti OR ‘side effect*’:ab,ti OR ‘undesirable effect*’:ab,ti OR ‘treatment emergent’:ab,ti OR tolerability:ab,ti OR toxic*:ab,ti OR adrs:ab,ti OR damag*:ab,ti OR impair*:ab,ti OR disorder*:ab,ti OR abuse*:ab,ti OR addict*:ab,ti OR withdrawal*:ab,ti OR ‘adverse effect’:ab,ti OR ‘adverse effects’:ab,ti OR ‘adverse reaction’:ab,ti OR ‘adverse reactions’:ab,ti OR ‘adverse event’:ab,ti OR ‘adverse events’:ab,ti OR ‘adverse outcome’:ab,ti OR ‘adverse outcomes’:ab,ti | 4,055,060
#28 | #26 OR #27 | 4,059,085
#29 | #25 AND #28 | 25,939
#30 | #25 AND #28 AND ([cochrane review]/lim OR [systematic review]/lim OR [meta analysis]/lim) | 373
#31 | #25 AND #28 AND ([cochrane review]/lim OR [systematic review]/lim OR [meta analysis]/lim) AND [embase]/lim | 335
#32 | #25 AND #28 ([cochrane review]/lim OR [systematic review]/lim OR [meta analysis]/lim) AND [embase]/lim AND [english]/lim | 319
#33 | #14 OR #24 OR #33 | 2,616
#34 | #33 NOT [medline]/lim | 1,592

### PSYCINFO 1806 to May Week 1 2016

Date Searched: Tuesday May 10, 2016

# | Searches | Results
1 | cannabis/ or hashish/ or marijuana/ or exp cannabinoids/ or tetrahydrocannabinol/ or cannabinoids/ or tetrahydrocannabinol/ or marijuana usage/ or marijuana/ | 11208
2 | (cannabis or canabis or cannabinoid* or cannabidiol* or CBD or cannabacae or marijuana or marihuana or hashish or hash or ganja or ganjah or hemp or bhang or charas or THC or tetrahydrocannabinol* or tetra-hydrocannabinol* or 9?tetrahydrocannabinol* or DELTA?9?-tetrahydrocannabinol*).tw. | 19269
3 | 1 or 2 | 19585
4 | pain/ or aphagia/ or back pain/ or chronic pain/ or headache/ or myofascial pain/ or neuralgia/ or neuropathic pain/ or somatoform pain disorder/ or headache/ or migraine headache/ or muscle contraction headache/ or neuralgia/ or trigeminal neuralgia/ or pain management/ | 50895
5 | (pain or pains or painful* or migraine* or headache* or neuropath* or neuralgia* or arthriti* or fibromyalg*).tw. | 116341
6 | 4 or 5 | 117164
7 | 3 and 6 | 915
8 | limit 7 to human | 599
9 | limit 7 to animal | 346
10 | 7 not (8 or 9) | 35
11 | 8 or 10 | 634
12 | limit 11 to english language | 582
13 | limit 12 to (“column/opinion” or “comment/reply” or editorial or “erratum/correction” or letter) | 54
14 | 12 not 13 | 528
15 | cross-section*.tw. | 54490
16 | 14 not 15 | 505
17 | posttraumatic stress disorder/ or complex ptsd/ or desnos/ | 25127
18 | (PTSD or post-traumatic stress or posttraumatic stress).tw. | 33843
19 | 17 or 18 | 35163
20 | 3 and 19 | 209
21 | limit 20 to human | 178
22 | limit 20 to animal | 33
23 | 20 not (21 or 22) | 12
24 | 21 or 23 | 190
25 | limit 24 to english language | 173
26 | limit 25 to (“column/opinion” or “comment/reply” or editorial or letter) | 9
27 | 25 not 26 | 164
28 | cross-section*.tw. | 54490
29 | 27 not 28 | 155
30 | (harm or harms or harmful or safe or safety or side effect* or undesirable effect* or treatment emergent or tolerability or toxic* or adrs or damag* or impair* or disorder* or abuse* or addict* or withdrawal* or (adverse adj2 (effect or effects or reaction or reactions or event or events or outcome or outcomes))).tw. | 816214
31 | 3 and 30 | 10099
32 | limit 31 to (“0830 systematic review” or 1200 meta analysis) | 111
33 | 16 or 29 or 32 | 750

### EBM Reviews Databases

- Cochrane Central Register of Controlled Trials April 2016,
- Cochrane Database of Systematic Reviews 2005 to May 05, 2016,
- Database of Abstracts of Reviews of Effects 1st Quarter 2016,
- Health Technology Assessment 2nd Quarter 2016,
- NHS Economic Evaluation Database 1st Quarter 2016

Date Searched: Tuesday May 10, 2016

# (http://ovidsp.tx.ovid.com.liboff.ohsu.edu/sp-3.20.0b/ovidweb.cgi?&S=OELBFPIMOIDDNMGDNCIKDFIBDEPHAA00&Sort+Sets=descending) | Searches | Results
1 | (cannabis or canabis or cannabinoid* or cannabidiol* or CBD or cannabacae or marijuana or marihuana or hashish or hash or ganja or ganjah or hemp or bhang or charas or THC or tetrahydrocannabinol* or tetra-hydrocannabinol* or 9?tetrahydrocannabinol* or DELTA?9?-tetrahydrocannabinol*).tw. | 2318
2 | (pain or pains or painful* or migraine* or headache* or neuropath* or neuralgia* or arthriti* or fibromyalg*).tw. | 100259
3 | 1 and 2 | 262
4 | (PTSD or post-traumatic stress or posttraumatic stress).tw. | 2401
5 | 1 and 4 | 20
6 | (harm or harms or harmful or safe or safety or side effect* or undesirable effect* or treatment emergent or tolerability or toxic* or adrs or damag* or impair* or disorder* or abuse* or addict* or withdrawal* or (adverse adj2 (effect or effects or reaction or reactions or event or events or outcome or outcomes))).tw. | 274193
7 | 1 and 6 | 1227
8 | (meta-review* or meta-epidemiolog* or metaepidemiolog* or “horizon scan*” or ((systematic* or “systematic effectiveness” or “comparative effectiveness” or evidence or landscape or methodologic or methodological or quantitative or qualitative or integrative or mixed-method* or “mixed method*” or research or scoping or umbrella or “review* of” or updat* or cochrane or campbell) adj review*) or ((research* or evidence) adj2 aggregat*) or “evidence map*” or “evidence brief*” or “evidence summar*” or ((rapid or mini* or pragmatic or targeted or focused or brief or short*) adj2 (systematic or evidence or knowledge or review* or synthes*)) or meta-analy* or metaanaly* or “meta-meta-analy*” or “evidence synthes*” or “knowledge synthes*” or “quantitative synthes*” or “qualitative synthes*” or “research synthes*” or “integrat* data analys*” or (integrative adj1 analys?s) or “pooled analy*” or (indirect* adj2 comparison*) or (mixed* adj2 comparison*) or ((reliability or validity) adj generali?ation*) or meta-aggregat* or metaaggregat* or meta-ethnograph* or metaethnograph* or meta-interpret* or metainterpret* or meta-narrative* or metanarrative* or meta-review* or metareview* or meta-stud* or metastud* or meta-summar* or metasummar* or meta-synth* or metasynth* or “narrative synth*” or “narrative review*” or “qualitative comparative analy*” or “qualitative cross-case” or realist-synth* or “realist synth*” or “realist review*” or “thematic synth*” or “summary receiver operating characteristic*” or “comparative case study” or “comparative case studies”).ti,ab. | 41555
9 | 7 and 8 | 116
10 | 3 or 5 or 9 | 343
11 | remove duplicates from 10 | 334
12 | limit 11 to english language | 308

### PILOTS: Published International Literature On Traumatic Stress Database

(http://www.ptsd.va.gov/professional/pilots-database/)

Date Searched: Tuesday May 10, 2016

ab(cannabis OR canabis OR cannabinoid* OR cannabidiol* OR CBD OR cannabacae OR marijuana OR marihuana OR hashish OR hash OR ganja OR ganjah OR hemp OR bhang OR charas OR THC OR tetrahydrocannabinol* OR tetra-hydrocannabinol* OR 9?tetrahydrocannabinol* OR DELTA?9?-tetrahydrocannabinol*) AND (PTSD OR posttraumatic stress OR post-traumatic stress) = 177 results

### COS Conference Papers Index

Date Searched: Tuesday May 17, 2016

Set (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview:toggellistorder?site=cpi&t:ac=RecentSearches) | Search | Results
S4 | S1 or S2 (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink:rerunsearch/94DFEB888D5544C6PQ/None?site=cpi&t:ac=RecentSearches) | 711° (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink_0:rerunsearch/94DFEB888D5544C6PQ/None?site=cpi&t:ac=RecentSearches)
S3 | (cannabis OR canabis OR cannabinoid* OR cannabidiol* OR CBD OR cannabacae OR marijuana OR marihuana OR hashish OR hash OR ganja OR ganjah OR hemp OR bhang OR charas OR THC OR tetrahydrocannabinol* OR tetra-hydrocannabinol* OR 9?tetrahydrocannabinol* OR DELTA?9?-tetrahydrocannabinol*) AND (harm or harms or harmful or safe or safety or side effect* or undesirable effect* or treatment emergent or tolerability or toxic* or adrs or damag* or impair* or disorder* or abuse* or addict* or withdrawal* or (adverse NEAR/2 (effect or effects or reaction or reactions or event or events or outcome or outcomes))) (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink:rerunsearch/206817BD987F441DPQ/None?site=cpi&t:ac=RecentSearches)Limits applied | 532° (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink_0:rerunsearch/206817BD987F441DPQ/None?site=cpi&t:ac=RecentSearches)
S2 | (cannabis OR canabis OR cannabinoid* OR cannabidiol* OR CBD OR cannabacae OR marijuana OR marihuana OR hashish OR hash OR ganja OR ganjah OR hemp OR bhang OR charas OR THC OR tetrahydrocannabinol* OR tetra-hydrocannabinol* OR 9?tetrahydrocannabinol* OR DELTA?9?-tetrahydrocannabinol*) AND (PTSD or post-traumatic stress or posttraumatic stress) (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink:rerunsearch/A2C84E0729D34739PQ/None?site=cpi&t:ac=RecentSearches)Limits applied | 4° (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink_0:rerunsearch/A2C84E0729D34739PQ/None?site=cpi&t:ac=RecentSearches)
S1 | (cannabis or canabis or cannabinoid* or cannabidiol* or CBD or cannabacae or marijuana or marihuana or hashish or hash or ganja or ganjah or hemp or bhang or charas or THC or tetrahydrocannabinol* or tetra-hydrocannabinol* or 9?tetrahydrocannabinol* or DELTA?9?-tetrahydrocannabinol*) AND (pain or pains or painful* or migraine* or headache* or neuropath* or neuralgia* or arthriti* or fibromyalg*) (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink:rerunsearch/D4CFB313A97F4D24PQ/None?site=cpi&t:ac=RecentSearches)Limits applied | 176° (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink_0:rerunsearch/D4CFB313A97F4D24PQ/None?site=cpi&t:ac=RecentSearches)

### ClinicalTrials.gov

Date Searched: Monday May 16, 2015

Chronic Pain Search
( pain OR pains OR painful* OR migraine* OR headache* OR neuropath* OR neuralgia* OR arthriti* OR fibromyalg* ) [DISEASE] AND ( cannabis OR canabis OR cannabinoid* OR cannabidiol* OR CBD OR cannabacae OR marijuana OR marihuana OR hashish OR hash OR ganja OR ganjah OR hemp OR bhang OR charas OR THC OR tetrahydrocannabinol* OR tetra-hydrocannabinol* OR 9tetrahydrocannabinol* OR Δ9-THC ) [TREATMENT] = 74 results

Post-traumatic Stress Disorder (PTSD) Search
( PTSD OR post-traumatic stress OR posttraumatic stress ) [DISEASE] AND ( cannabis OR canabis OR cannabinoid* OR cannabidiol* OR CBD OR cannabacae OR marijuana OR marihuana OR hashish OR hash OR ganja OR ganjah OR hemp OR bhang OR charas OR THC OR tetrahydrocannabinol* OR tetrahydrocannabinol* OR 9tetrahydrocannabinol* ) [TREATMENT] = 6 results

Harms Search
( harm* OR safety OR “side effect*” OR “undesirable effect*” OR “treatment emergent” OR tolerability OR toxic* OR adrs OR damag* OR impair* OR abuse* OR addict* OR withdrawal* OR “adverse effect*” OR “adverse event*” OR “adverse outcome*” ) AND ( ( cannabis OR canabis OR cannabinoid* OR cannabidiol* OR CBD OR cannabacae OR marijuana OR marihuana OR hashish OR hash OR ganja OR ganjah OR hemp OR bhang OR charas OR THC OR tetrahydrocannabinol* OR tetra-hydrocannabinol* OR 9tetrahydrocannabinol* ) AND NOT ( sativex OR namisol OR POT-4 OR Levodopa OR Carbidopa ) ) [TREATMENT] = 65 results

### WHO ICTRP Database

Date Searched: Wednesday May 18, 2016

*Due to the 256 character limit for searches, the following searches were edited to fit within the proscribed limits. All terms removed were searched separately and found to not change or add additional results compared to the searches below.

Chronic Pain Search
CONDITION = (pain or pains or painful* or migraine* or headache* or neuropath* or neuralgia* or arthriti* or fibromyalg*) AND INTERVENTION=(cannabis or canabis or cannabinoid* or cannabidiol* or CBD or cannabacae or marijuana or hashish or hash or ganja or ganjah or hemp or THC or tetrahydrocannabinol* or tetrahydrocannabinol* or 9-tetrahydrocannabinol* or DELTA-9-tetrahydrocannabinol*) = 45 results [24 results were from ClinicalTrials.gov, therefore only 21 results were downloaded]

Post-traumatic Stress Disorder (PTSD) Search
CONDITION = (PTSD or post-traumatic stress or posttraumatic stress) AND INTERVENTION=(cannabis or canabis or cannabinoid* or cannabidiol* or CBD or cannabacae or marijuana or hashish or hash or ganja or ganjah or hemp or THC or tetrahydrocannabinol* or tetrahydrocannabinol* or 9-tetrahydrocannabinol* or DELTA-9-tetrahydrocannabinol*) = 4 results [all results were from so no results were downloaded]

Harms Search
CONDITION = (harm* or safe or safety or side effect* or undesirable effect* or tolerability or toxic* or adrs or damag* or impair* or disorder* or abuse* or addict* or withdrawal* or adverse effect* or adverse reaction* or adverse event* or adverse outcome*) AND INTERVENTION=(cannabis or canabis or cannabinoid* or cannabidiol* or CBD or cannabacae or marijuana or hashish or hash or ganja or ganjah or hemp or THC or tetrahydrocannabinol* or tetrahydrocannabinol* or 9-tetrahydrocannabinol* or DELTA-9-tetrahydrocannabinol*) = 203 results [108 results were from ClinicalTrials.gov, therefore only 95 results were downloaded]

### ISRCTN Registry

Date Searched: Tuesday May 24, 2016

Text search: cannabis or canabis or cannabinoid or cannabidiol or CBD or cannabacae or marijuana or marihuana or hashish or hash or ganja or ganjah or hemp or bhang or charas or THC or tetrahydrocannabinol or tetra-hydrocannabinol or 9-tetrahydrocannabinol or DELTA-9-tetrahydrocannabinol (each keyword searched individually and results reviewed) = 8 results

### NIH RePORTER

Date Searched: Monday May 16, 2016

Chronic Pain Search
((cannabis OR canabis OR cannabinoid OR cannabidiol OR CBD OR cannabacae OR marijuana OR marihuana OR hashish OR hash OR ganja OR ganjah OR hemp OR bhang OR charas OR THC OR tetrahydrocannabinol OR tetra-hydrocannabinol OR 9tetrahydrocannabinol) AND (pain OR pains OR painful OR migraine OR migraines OR headache OR headaches OR neuropathy OR neuropathies OR neuralgia OR arthritis OR fibromyalgia)) \| Search in: Projects \| Limit Project Search To: Project Title,Project Abstracts \| Limit Publication Search To: 2015-2016 = 50 results

Post-traumatic Stress Disorder (PTSD) Search
((cannabis OR canabis OR cannabinoid OR cannabidiol OR CBD OR cannabacae OR marijuana OR marihuana OR hashish OR hash OR ganja OR ganjah OR hemp OR bhang OR charas OR THC OR tetrahydrocannabinol OR tetra-hydrocannabinol OR 9tetrahydrocannabinol) AND (PTSD OR post-traumatic stress OR posttraumatic stress)) Search in: Projects \| Limit Project Search To: Project Title,Project Abstracts \| Limit Publication Search To: 2015-2016 = 5 results

Harms Search
((cannabis OR canabis OR cannabinoid OR cannabidiol OR CBD OR cannabacae OR marijuana OR marihuana OR hashish OR hash OR ganja OR ganjah OR hemp OR bhang OR charas OR THC OR tetrahydrocannabinol OR tetra-hydrocannabinol OR 9tetrahydrocannabinol) AND (harm OR harms OR harmful OR safe OR safety OR “side effects” OR “undesirable effects” OR “treatment emergent” OR tolerability OR toxicity OR adrs OR damage OR impaired OR impairing OR abuse OR addicted OR addiction OR addictions OR withdrawal OR “adverse effects” OR “adverse events” OR “adverse outcomes”)) (Advanced), Search in: Projects \| Limit Project Search To: Project Title,Project Abstracts \| Limit Publication Search To: 2015-2016 = 220 results

### AHRQ Gold (Grants On-Line Database)

Date Searched: Monday May 16, 2016

cannabis OR canabis OR cannabinoid OR cannabidiol OR CBD OR cannabacae OR marijuana OR marihuana OR hashish OR hash OR ganja OR ganjah OR hemp OR bhang OR charas OR THC OR tetrahydrocannabinol OR tetra-hydrocannabinol OR 9tetrahydrocannabinol = 0 results