# SUMMARY AND DISCUSSION

We identified five SRs of CAM therapies for depressive and anxiety disorders that were of good or fair quality. All five reviews evaluated mind-body CAM therapies (KQ 1). We found no synthesized evidence of acceptable quality for manipulative and body-based CAM therapies (KQ 2) or CAM movement-based or energy therapies (KQ 3). We summarize the findings below:

- Overall, few recent good- or fair-quality systematic reviews have evaluated CAM therapies of interest for depressive and anxiety disorders.
- For anxiety disorders, there is limited evidence on the effectiveness of meditation (n = 2 studies). Studies reported high rates of dropout, suggesting that adherence to meditation may be problematic in a clinical setting. With so few studies of moderate quality and a small number of participants completing treatments, it is difficult to draw conclusions about the efficacy of meditation for the treatment of anxiety disorders.
- Relaxation and/or breathing retraining show promise as a CAM therapy for panic disorders; however, evidence is limited.
- Acupuncture shows some promise as a CAM therapy for depression; however, results were mixed. For MDD, acupuncture showed greater effects than sham control on depressive symptoms but did not improve response or remission rates. In a fair-quality review, acupuncture did not differ significantly from short-term use of antidepressants. For patients with post-stroke depression, acupuncture was more effective than short-term use of antidepressants.
- Mindfulness-based stress reduction has shown positive effects on anxiety and depressive symptoms; however, studies are poor to fair quality.
- Most SR studies evaluated small trials that did not provide adequate descriptions of CAM strategies to permit replication. Dose, duration, and frequency of interventions sometimes varied widely, which, in turn, influenced estimates of pooled effects.
- No included SRs reported effects on health-related quality of life. Reported results provided limited data on adverse effects or retention rates.
- The limitations of the current synthesized evidence preclude strong conclusions about specific CAM interventions for the treatment of depressive and anxiety disorders. However, limited evidence supports the use of meditation, relaxation training and/or breathing retraining, and mindfulness-based stress reduction for anxiety and acupuncture for depression.

The available evidence on CAM treatments for anxiety or depression has important limitations but identifies a small number of therapies that have at least some evidence of positive effects. This evidence should be considered together with the direct data on CAM treatments for PTSD when planning further treatment studies. Meditation, relaxation and breathing retraining, mindfulness-based stress reduction, and acupuncture showed some limited promise for select populations with anxiety or depressive symptoms. In our review of CAM for PTSD,7 we found moderate evidence for benefits from acupuncture and low-quality evidence for meditation. Thus, by broadening our review to include closely related conditions, we have identified two additional CAM treatments that should be considered for further evaluation in patients with PTSD.

We did not identify any SRs of good or fair quality that synthesized the evidence for manipulative and body-based CAM therapies or CAM movement-based or energy therapies for depressive and anxiety disorders. Future studies should seek to summarize the available evidence on these CAM modalities; however, a dearth of primary studies may preclude synthesis. As noted in the Efficacy of Complementary and Alternative Medicine Therapies for Posttraumatic Stress Disorder7 report, designing rigorous tests of some CAM modalities may be difficult since sham procedures that are both truly inert and appear sufficiently similar to the active intervention are challenging to devise. Future research may want to test these strategies in small exploratory trials if there is a sufficient theoretical rationale for a beneficial treatment effect.