# RESULTS

## LITERATURE SEARCH

We identified 194 unique SRs from a combined search of MEDLINE (via PubMed with SR filter applied, n = 133) and the Cochrane Database of Systematic Reviews (n = 61). Another potentially relevant review was identified from citations. Of these, 175 were excluded at the title-and-abstract level most often because the population was not adult, the population was not diagnosed with a depressive disorder or anxiety disorder other than PTSD, or the active intervention was not a form of CAM therapy of interest for this report.

An additional 15 studies were excluded following a review of the full text of the 20 articles. Four of these studies were not SRs,16-19 one was poor quality,20 four primarily reviewed treatment interventions that were not the CAM therapies of interest21-24 and six examined populations who were not diagnosed with depressive disorders or an anxiety disorder other than PTSD by valid criteria; e.g., Diagnostic Statistical Manual of Mental Disorders (DSM).25-30 A table listing these studies and their reasons for exclusion is found in Appendix D. In total, five SRs met eligibility criteria and are summarized by KQ.

## KQ 1 In adults with depressive or anxiety disorders, are mind-body complementary and alternative medicine therapies (e.g., acupuncture, yoga, meditation) more efficacious than control for PTSD symptoms and health-related quality of life?

We identified five relevant SRs, two that assessed CAM therapies for depressive disorders,31, 32 two that assessed CAM therapies for anxiety disorders,33, 34 and one that assessed CAM therapies for anxiety or depressive disorders.35 These are summarized below.

### Depressive disorders mind-body CAM therapies

#### Wang, 2008. Is acupuncture beneficial in depression: A meta-analysis of 8 randomized controlled trials? (Quality rating: Good)

Study summary: The objective of this good-quality report was to synthesize the evidence for the benefit of acupuncture as a treatment for depression. To be eligible for inclusion in this review, studies had to be randomized clinical trials that compared traditional acupuncture as the active intervention with sham acupuncture as the control group in patients with a diagnosis of MDD or depressive neurosis by accepted diagnostic criteria. Acupuncture treatment ranged from 10 to 30 sessions.

Key findings: The authors identified eight small, moderate- to high-quality trials that were included in a meta-analysis (n = 477 patients). Outcome measures were the Hamilton Rating Scale for Depression or the Beck Depression Inventory. A pooled analysis of the depression scores calculated a standardized mean difference (SMD) of -0.65 (95% CI -1.18 to -0.11) indicating greater reduction in depressive symptoms among patients randomized to acupuncture. However, response rates (≥ 50% reduction in symptoms) and remission rates did not differ between active and sham treatments. Six of the eight trials reported response rates for acupuncture compared to sham treatment (RR 1.32; 95% CI 0.83 to 2.10). Remission rates were measured in only four of the eight studies, and no significant difference was found between groups (RR 1.30, 95% CI 0.57 to 2.95).

Considerations: There was a large degree of heterogeneity (I^2^ = 67.9 to 84.1%) among the studies: high diversity in the number of sessions; the length of the studies' active treatment phase; the type of randomization; and the type of acupuncture – four had individually chosen sites while the other four used fixed points. The high heterogeneity decreases confidence in the pooled estimate of effect.

#### Zhang, 2010. The effectiveness and safety of acupuncture therapy in depressive disorders: Systematic review and meta-analysis (Quality rating: Fair)

Study summary: The objective of this fair-quality report was to evaluate the effectiveness of acupuncture as monotherapy and as an additional therapy for depressive conditions. To be eligible for this review, a study needed to be a moderate- to high-quality (Jadad score >3) randomized, controlled trial, and patients had to be diagnosed with MDD by accepted diagnostic criteria or post-stroke depression (PSD) by neuroimaging verification of brain alteration. Acupuncture treatment ranged from 15 to 60 sessions. Control conditions were sham acupuncture (n = 3 MDD; n = 0 PSD), antidepressant medication (n = 15 MDD; n = 12 PSD) or waitlist (n = 1 MDD; n = 3 PSD). Treatment was short term (median = 6 weeks for MDD and 4 weeks for PSD).

Key findings: The review identified 20 trials (n = 1998 patients) on MDD and 15 trials (n = 1680 patients) on PSD. Most trials were conducted in China. In nine trials of MDD (n = 662 patients), there was no significant difference between acupuncture as monotherapy versus antidepressant treatment on change in depressive symptoms (mean difference -0.31, 95% CI -0.94 to 1.56) or response rates (RR = 1.09, 95% CI = 0.92 to 1.30). Other comparisons, acupuncture versus sham acupuncture, waitlist or as adjunctive therapy also did not yield significant differences in response rates. There was some evidence in two trials that acupuncture as an adjunct to antidepressant treatment improved symptom severity (WMD^*^ = 2.38, 95% CI = 0.62 to 4.12) with low heterogeneity (I^2^ = 0%), but response rates were not significantly improved. Conversely, for PSD, 11 trials (n = 708) comparing acupuncture as monotherapy versus antidepressant showed a greater response rate for acupuncture (RR^†^ = 1.31, 95% CI = 1.19 to 1.44) with low heterogeneity (I^2^ = 0%). Similar effects were obtained for measuring change in symptom severity. Fewer adverse effects were found with acupuncture in 21 of 35 trials reporting this information.

* Weighted mean difference

† Relative risk

Considerations: There was a large degree of heterogeneity (I^2^ = 68-94%) in most comparisons among these trials in the type of acupuncture, the number of acupuncture sessions and the length of treatment (4 to 12 weeks). In 27 of 35 trials, the comparator was antidepressant. Only three of the eight sham controlled trials evaluated by Wang et al.31 were included in this study. When heterogeneity was controlled by removing outliers, results did not change. Given the degree of heterogeneity, any conclusion about acupuncture as therapy for MDD must be interpreted with caution; however, there is evidence that high-intensity acupuncture may be effective for PSD. Finally, most studies were conducted in China and did not provide detailed information about the study population; therefore, results may not be applicable to U.S. Veterans.

#### Hofmann, 2010. The effect of mindfulness-based therapy on anxiety and depression: A meta-analytic review (Quality rating: Fair)

Study Summary: The objective of this fair-quality review was to quantitatively synthesize the evidence on mindfulness-based therapies (MBT) for the treatment of anxiety or depression. To be eligible for this evidence synthesis, studies needed to evaluate mindfulness-based treatment, either mindfulness-based cognitive therapy (MBCT) or mindfulness-based stress reduction (MBSR) in adults age 18 to 65, with a diagnosable psychological or physical/medical disorder and report sufficient data to calculate effect sizes for anxiety and/or depressive outcomes. Comparative and noncomparative studies were included.

Key findings: The review included 39 studies (n = 1,140 patients); primary studies were fair to poor quality (median quality score = 1 on a 0 to 5 point scale, with 5 being highest quality). Of the 39 studies, 16 were controlled studies, and most (n = 11) compared MBT to waitlist or usual care; 15 were conducted in patient samples relevant to this summary (anxiety or depressive disorder). Across all studies, MBT was associated with improved anxiety symptoms (Hedges g 0.63, 95% CI 0.53 to 0.73) and depressive symptoms (Hedges g 0.59, 95% CI 0.51 to 0.66). Extensive sensitivity analysis showed similar effects for those treated with MBCT and MBSR, controlled and uncontrolled studies, and those reporting intent-to-treat analyses.

Considerations: This review evaluated a highly heterogeneous, poor-quality group of studies. Many of the studies used MBCT, a treatment derived from cognitive behavioral therapy and considered to be a mainstream therapy.

### Anxiety disorders mind-body CAM therapies:

#### Krisanaprakornkit, 2006. Meditation therapy for anxiety disorders (Quality rating: Good)

Study summary: The objective of this good-quality report was to synthesize the evidence of meditation therapy for the treatment of anxiety disorders. To be eligible for this evidence review, studies needed to be randomized, controlled trials of concentrative or mindfulness meditation with either an active comparator (i.e., pharmacotherapy, psychological treatments, other meditation methods) or no treatment control.

Key findings: The review identified only two eligible trials,36, 37 both of moderate quality and conducted in the U.S. Included studies were too varied to pool results. Raskin36 compared the effectiveness of transcendental meditation, muscle biofeedback, and relaxation training (n = 55). All three conditions reported significant improvement in anxiety symptoms (F = 7.26; df = 1,27; P<0.01), as measured by the Taylor Manifest Anxiety Scale Score. Shannahoff 37 reported on the effectiveness of Kundalini yoga versus mindfulness meditation for participants with obsessive compulsive disorder (n = 21) and found no significant differences on the primary outcome measure (Yale-Brown Obsessive-Compulsive Scale). Two secondary measures, the Perceived Stress Scale and Purpose In Life Scale, showed significant differences favoring Kundalini yoga.

Considerations: Both included studies excluded participants with substance use disorders. Shannahoff 37 also excluded participants who smoked, had spinal/physical issues (e.g., pulmonary disorders, overweight, hypertension, and other cardiovascular issues), or who had another primary psychiatric condition (e.g., MDD, bipolar disorder, schizophrenia). Moreover, dropout rates were high in both studies (44% for Raskin36 and 33% for Shannahoff 37).

#### Sanchez-Meca, 2010. Psychological treatment of panic disorder with or without agoraphobia: A meta-analysis (Quality rating: Fair)

Study summary: The objective of this fair-quality report was to analyze the efficacy of psychological interventions for the treatment of panic disorder with or without agoraphobia. Much of this evidence review focused on non-CAM therapies. Only the CAM-specific results (i.e., relaxation and breathing retraining) are summarized here. To be eligible for this evidence review, studies met the following criteria: recruited participants with panic disorder with no less than five participants, tested psychological treatments only (no adjunctive pharmacotherapy) in experimental arm with a nonactive (e.g., waitlist) or active (e.g., pharmacotherapy, other psychological treatment) comparator, and published between 1980 and 2006 in French or English.

Key findings: Authors identified 42 eligible reports encompassing 65 comparisons. Only three included studies were comparisons of relaxation training and/or breathing retraining (total participants not reported). Relaxation training and breathing retraining improved measures of panic disorder (d_+_ = 0.862, 95% CI 0.203-1.521) compared to nonactive or active control.

Considerations: This report provided no details on comparator conditions. Also, much of this report is devoted to non-CAM therapies, with only three included studies of CAM-specific therapies. Details on the interventions used were sparse.

## KQ 2 In adults with depressive or anxiety disorders, are manipulative and body-based complementary and alternative medicine therapies (e.g., spinal manipulation, massage) more efficacious than control for PTSD symptoms and health-related quality of life?

We found no relevant SRs of good or fair quality.

## KQ 3 In adults with depressive or anxiety disorders, are complementary and alternative medicine therapies that are movement-based or involve energy therapies more efficacious than control for PTSD and health-related quality of life?

We found no relevant SRs of good or fair quality.