# REFERENCES

1 Friedman MJ. Acknowledging the psychiatric cost of war. N. Engl. J. Med. Jul. 1. 2004;351(1):75-77. [pmid: 15229311].
2 Kessler RC, Davis RB, Foster DF, et al. Long-term trends in the use of complementary and alternative medical therapies in the United States. Ann. Intern. Med. Aug. 21. 2001;135(4):262-268. [pmid: 11511141].
3 Barnes PM, Bloom B, Nahin RL. Complementary and alternative medicine use among adults and children: United States, 2007. Natl Health Stat Report. Dec. 10. 2008;(12):1-23. [pmid: 19361005].
4 Unutzer J, Klap R, Sturm R, et al. Mental disorders and the use of alternative medicine: results from a national survey. A. J. Psychiatry. Nov. 2000;157(11):1851-1857.
5 Kessler RC, Soukup J, Davis RB, et al. The use of complementary and alternative therapies to treat anxiety and depression in the United States. A. J. Psychiatry. Feb. 2001;158(2):289-294.
6 Smith TC, Ryan MA, Smith B, et al. Complementary and alternative medicine use among US Navy and Marine Corps personnel. BMC Complement Altern Med. 2007;7:16. [pmid: 17506899].
7 Strauss JL, Coeytaux R, McDuffie J, Nagi A, Williams JWJ. Efficacy of Complementary and Alternative Therapies for Posttraumatic Stress Disorder VA-ESP Project #09-010. 2011.
8 Badura AS. Theoretical and empirical exploration of the similarities between emotional numbing in posttraumatic stress disorder and alexithymia. J. Anxiety Disord. 2003;17(3):349-360. [pmid: 12727127].
9 Kessler RC, Sonnega A, Bromet E, Hughes M, Nelson CB. Posttraumatic stress disorder in the National Comorbidity Survey. Arch. Gen. Psychiatry. Dec. 1995;52(12):1048-1060. [pmid: 7492257].
10 Brady KT, Clary CM. Affective and anxiety comorbidity in post-traumatic stress disorder treatment trials of sertraline. Compr. Psychiatry. Sep-Oct. 2003;44(5):360-369. [pmid: 14505296].
11 Dozois DJ, Frewen PA. Specificity of cognitive structure in depression and social phobia: a comparison of interpersonal and achievement content. J. Affect. Disord. Feb. 2006;90(2-3):101-109. [pmid: 16343641].
12 Goldberg DP, Krueger RF, Andrews G, Hobbs MJ. Emotional disorders: cluster 4 of the proposed meta-structure for DSM-V and ICD-11. Psychol. Med. Dec. 2009;39(12):2043-2059. [pmid: 19796429].
13 Effectiveness of Continuing Medical Education, Structured Abstract. Agency for Healthcare Research and Quality. Rockville, M.D. http://www.ahrp.gov/clinic/tp/cmetp.htm. February. 2007.
14 Moher D, Cook DJ, Eastwood S, Olkin I, Rennie D, Stroup DF. Improving the quality of reports of meta-analyses of randomised controlled trials: the QUOROM statement. Quality of Reporting of Meta-analyses. Lancet. Nov. 27. 1999;354(9193):1896-1900. [pmid: 10584742].
15 Shea BJ, Grimshaw JM, Wells GA, et al. Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC Med Res Methodol. 2007;7:10. [pmid: 17302989].
16 van der Watt G, Laugharne J, Janca A. Complementary and alternative medicine in the treatment of anxiety and depression. Curr Opin Psychiatry. Jan. 2008;21(1):37-42. [pmid: 18281839].
17 Halbreich U. Systematic reviews of clinical trials of acupuncture as treatment for depression: how systematic and accurate are they?. CNS Spectr. Apr. 2008;13(4):293-294. 299. 300. [pmid: 18408648].
18 Uebelacker LA, Epstein-Lubow G, Gaudiano BA, Tremont G, Battle CL, Miller IW. Hatha yoga for depression: critical review of the evidence for efficacy, plausible mechanisms of action, and directions for future research. J Psychiatr Pract. Jan. 2010;16(1):22-33. [pmid: 20098228].
19 Teixeira MZ, Guedes CH, Barreto PV, Martins MA. The placebo effect and homeopathy. Homeopathy. Apr. 2010;99(2):119-129. [pmid: 20471615].
20 Even C, Schroder CM, Friedman S, Rouillon F. Efficacy of light therapy in nonseasonal depression: a systematic review. J. Affect. Disord. May. 2008;108(1-2):11-23. [pmid: 17950467].
21 Freeman MP, Mischoulon D, Tedeschini E, et al. Complementary and alternative medicine for major depressive disorder: a meta-analysis of patient characteristics, placebo-response rates, and treatment outcomes relative to standard antidepressants. J. Clin. Psychiatry. Jun. 2010;71(6):682-688. [pmid: 20573327].
22 Li C, He Y, Yu D, Wang J, Omori Ichiro M, Xiao Z. Morita therapy for anxiety disorder, Cochrane Database of Systematic Reviews. 2010;(7). http://www.mrw.interscience.wiley.com/cochrane/clsysrev/articles/CD008619/frame.html.
23 Thachil AF, Mohan R, Bhugra D. The evidence base of complementary and alternative therapies in depression. J. Affect. Disord. Jan. 2007;97(1-3):23-35. [pmid: 16926053].
24 Tsang HW, Chan EP, Cheung WM. Effects of mindful and non-mindful exercises on people with depression: a systematic review. Br. J. Clin. Psychol. Sep. 2008;47(Pt 3):303-322. [pmid: 18237457].
25 Bohlmeijer E, Prenger R, Taal E, Cuijpers P. The effects of mindfulness-based stress reduction therapy on mental health of adults with a chronic medical disease: a meta-analysis. J. Psychosom. Res. Jun. 2010;68(6):539-544. [pmid: 20488270].
26 Coelho HF, Boddy K, Ernst E. Massage therapy for the treatment of depression: a systematic review. Int. J. Clin. Pract. Feb. 2008;62(2):325-333. [pmid: 18081800].
27 Hou WH, Chiang PT, Hsu TY, Chiu SY, Yen YC. Treatment effects of massage therapy in depressed people: a meta-analysis. J. Clin. Psychiatry. Jul. 2010;71(7):894-901. [pmid: 20361919].
28 Lee MS, Pittler MH, Ernst E. Effects of reiki in clinical practice: a systematic review of randomised clinical trials. Int. J. Clin. Pract. Jun. 2008;62(6):947-954. [pmid: 18410352].
29 Meeks TW, Wetherell JL, Irwin MR, Redwine LS, Jeste DV. Complementary and alternative treatments for late-life depression, anxiety, and sleep disturbance: a review of randomized controlled trials. J. Clin. Psychiatry. Oct. 2007;68(10):1461-1471. [pmid: 17960959].
30 Shih M, Yang YH, Koo M. A meta-analysis of hypnosis in the treatment of depressive symptoms: a brief communication. Int. J. Clin. Exp. Hypn. Oct. 2009;57(4):431-442. [pmid: 20183000].
31 Wang H, Qi H, Wang BS, et al. Is acupuncture beneficial in depression: a meta-analysis of 8 randomized controlled trials?. J. Affect. Disord. Dec. 2008;111(2-3):125-134. [pmid: 18550177].
32 Zhang ZJ, Chen HY, Yip KC, Ng R, Wong VT. The effectiveness and safety of acupuncture therapy in depressive disorders: systematic review and meta-analysis. J. Affect. Disord. Jul. 2010;124(1-2):9-21. [pmid: 19632725].
33 Krisanaprakornkit T, Krisanaprakornkit W, Piyavhatkul N, Laopaiboon M. Meditation therapy for anxiety disorders. Cochrane Database Syst Rev. 2006;(1):CD004998. [pmid: 16437509].
34 Sanchez-Meca J, Rosa-Alcazar AI, Marin-Martinez F, Gomez-Conesa A. Psychological treatment of panic disorder with or without agoraphobia: a meta-analysis. Clin. Psychol. Rev. Feb. 2010;30(1):37-50. [pmid: 19775792].
35 Hofmann SG, Sawyer AT, Witt AA, Oh D. The effect of mindfulness-based therapy on anxiety and depression: A meta-analytic review. J. Consult. Clin. Psychol. Apr. 2010;78(2):169-183. [pmid: 20350028].
36 Raskin M, Bali LR, Peeke HV. Muscle biofeedback and transcendental meditation. A controlled evaluation of efficacy in the treatment of chronic anxiety. Arch. Gen. Psychiatry. Jan. 1980;37(1):93-97. [pmid: 6986134].
37 Shannahoff-Khalsa DS, Ray LE, Levine S, Gallen CC, Schwartz BJ, Sidorowich JJ. Randomized controlled trial of yogic meditation techniques for patients with obsessive-compulsive disorder. CNS Spectr. Dec. 1999;4(12):34-47. [pmid: 18311106].