# METHODS

This review was commissioned by the Department of Veterans Affairs' Evidence-based Synthesis Program. The key questions (KQs) were adapted from the original report, which addresed CAM treatments in patients with PTSD, to address CAM treatments in patients with depressive or anxiety disorders. CAM therapies are classified using categories proposed by the NCCAM, and the KQs reflect this classification:

KQ 1 In adults with depressive or anxiety disorders, are mind-body complementary and alternative medicine therapies (e.g., acupuncture, yoga, meditation) more efficacious than control for PTSD symptoms and quality of life?
KQ 2 In adults with depressive or anxiety disorders, are manipulative and body-based complementary and alternative medicine therapies (e.g., spinal manipulation, massage) more efficacious than control for PTSD symptoms and quality of life?
KQ 3 In adults with depressive or anxiety disorders, are complementary and alternative medicine therapies that are movement-based or involve energy therapies more efficacious than control for PTSD symptoms and quality of life?

## ANALYTIC FRAMEWORK

We developed and followed a standard protocol for all steps of this review. Our approach was guided by the analytic framework shown in Figure 1.

Figure 1 Analytic framework

Examples of interventions:

- Mind-body therapies: acupuncture, meditation, yoga, deep-breathing exercises, guided imagery, hypnotherapy, progressive relaxation, and tai chi
- Manipulative and body-based therapies: spinal manipulation and massage therapy
- Movement-based therapies: Feldenkrais method, Alexander technique, Pilates, Rolfing Structural Integration, and Trager Psychophysical Integration
- Energy therapies: magnet therapy, light therapy, qi gong, Reiki, and healing touch

## SEARCH STRATEGY, STUDY SELECTION AND DATA ABSTRACTION

We searched MEDLINE (via PubMed) and the Cochrane Database of Systematic Reviews for recent English-language SRs that evaluated eligible CAM treatments in patients with a depressive or anxiety disorder excluding PTSD, which was addressed in the main report. Search terms included a validated search filter to identify SRs, terms for eligible CAM treatments, and terms for depressive and anxiety disorders. We used the limit terms Publication Date from 2006/01/01 to 2011/07/01, English, and Humans. Detailed search terms are given in Appendix A. The computerized search was supplemented with a focused review of citations. Using prespecified inclusion/exclusion criteria, two reviewers assessed the list of titles and abstracts. Full-text articles, identified by either reviewer as potentially relevant, were retrieved for further review. Each article retrieved was reviewed by two reviewers using the eligibility criteria in Appendix B; disagreements were resolved by discussion or by a third reviewer. To be included in this report, an SR had to: (1) address one or more eligible CAM treatments in adults with a depressive disorder or anxiety disorder (excluding PTSD), (2) be published within the past 5 years, and (3) be evaluated as a “fair” or “good” quality SR. We used modified Assessment of Multiple Systematic Reviews (AMSTAR) criteria to rate the quality of identified reviews (Appendix C).13-15 A trained researcher wrote a structured abstract to summarize each review narratively; a second reviewer overread the abstract.