# STUDY QUALITY ASSESSMENT – SYSTEMATIC REVIEWS^*^ * Adapted from: 1. Effectiveness of Continuing Medical Education, Structured Abstract. February. 2007. Agency for Healthcare Research and Quality. Rockville, MD. http://www.ahrq.gov/clinic/tp/cmetp.htm. 2. Moher D, Cook DJ, Eastwood S, et al. Improving the quality of reports of meta-analyses of randomized controlled trials: The QUOROM statement. Lancet. 1999;354:1896-900. [pmid: 10584742]. 3. Shea BJ, Grimshaw JM, Wells GA, Boers M, Andersson N, Hamel C, Porter A, Tugwell P, Moher D, Bouter LM. Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC Medical Research Methodology. 2007;7:10. [pmid: 17302989].

For reviews, first determine whether it is a systematic review (SR). To be a systematic review, it must include a methods section that describes: (1) a search strategy, and (2) an a priori approach to synthesizing the data. For reviews determined to meet the SR criteria, assess methodological quality.

## General instructions

Step 1 Grade each of the criteria listed below as “Yes,” “No,” “Can't tell” or “Not Applicable”. Factors to consider when making an assessment are listed under each criterion. Where appropriate (particularly when assigning a “No,” or “Can't tell” score), please provide a brief rationale for your decision (in parentheses).
  1. Is a focused clinical question clearly stated?
    At a minimum, the question should be developed a priori and should clearly identify population and outcomes. The study question does not have to be in PICO (Population, Intervention, Comparisons, Outcomes) format.
  2. Are the search methods used to identify relevant studies clearly described?
    Search methods described in enough detail to permit replication. (The report must include years and databases used. Key words and/or MeSH terms must be stated and where feasible the search strategy should be provided.)
  3. Was a comprehensive literature search performed?
    At least two electronic sources should be searched. Electronic searches should be supplemented by consulting: reviews, textbooks, specialized registers, or experts in the field and by reviewing the references in the studies found. (OK to limit to key studies.)
  4. Are the inclusion/exclusion criteria used to screen primary studies clearly described?
    Inclusion/exclusion criteria described in enough detail to permit replication.
  5. Was there duplicate study selection and data extraction?
    Did two or more raters make inclusion/exclusion decisions, abstract data, and assess study quality – either independently or with one rater over-reading the first raters result?
    Was an appropriate method used to resolve disagreements (e.g., a consensus procedure)?
  6. Were the characteristics of the included studies provided?
    In an aggregated form such as a table, data from the original studies should be provided on the participants, interventions and outcomes. The ranges of characteristics in all the studies analyzed (e.g., age, race, sex, relevant socioeconomic data, disease status, duration, severity or other diseases) should be reported.
  7. Was the scientific quality of the included studies assessed and documented?
    A priori methods of assessment should be provided and criteria used to assess study quality specified in enough detail to permit replication.
  8. Were the methods used to combine the findings of studies appropriate?
    For pooled results, an accepted quantitative method of pooling should be used (i.e., more than simple addition; e.g., random-effects or fixed-effect model). For pooled results, a qualitative and quantitative assessment of homogeneity (Cochran's Q and/or I^2^) should be performed.
  9. Was the scientific quality of the included studies used appropriately in formulating conclusions?
    The results of the methodological rigor and scientific quality should be considered in the analysis (e.g. subgroup analyses) and the conclusions of the review, and explicitly stated in formulating recommendations.
  10. Was publication bias assessed?
    Publication bias tested using funnel plots, test statistics (e.g., Egger's regression test), and/or search of trials registry for unpublished studies.
  11. Was the conflict of interest stated?
    Potential sources of support should be clearly acknowledged in both the systematic review and the included studies.
  12. Are the stated conclusions supported by the data presented?
Step 2 Rate the overall quality of the SR as “Good,” “Fair,” or “Poor” using the guidance below.
  Good = After considering items 1 to 11, item 12 is rated “Yes” with no important limitations. This means that few of the items 1 to 11 are rated “No,” and none of the limitations are thought to decrease the validity of the conclusions.
  Fair = After considering items 1 to 11, item 12 is rated “Yes,” but with at least some important limitations. This means that enough of the items 1 to 11 are rated “No” to introduce some uncertainty about the validity of the conclusions.
  Poor = After considering items 1 to 11, item 12 is rated “No.” This means that several of items 1 to 11 are rated “No,” introducing serious uncertainty about the validity of the conclusions.