# ELIGIBILITY CRITERIA

Study characteristic | Inclusion criteria | Exclusion criteria
Study design | Fair- or good-quality systematic review | Non-English language publication Non-peer-reviewed publication
Population | Adults ≥ 19 diagnosed with depressive disorder or anxiety Depressive disorders could include: major depressive disorder, dysthymia, depressive disorder NOS, minor or subthreshold depression Anxiety disorders could include: generalized anxiety disorder, panic disorder, obsessive compulsive disorder, phobic disorders, acute stress disorder, anxiety disorder NOS, adjustment disorder with anxiety or mixed anxiety-depression | Seasonal affective disorder Post-partum depressive disorder Post traumatic stress disorder
Interventions | Any of the following eligible treatments:; - Mind-body therapies: acupuncture, meditation, yoga, deep-breathing exercises, guided imagery, hypnotherapy, progressive relaxation, and tai chi; - Manipulative and body-based therapies: spinal manipulation and massage therapy; - Movement-based therapies: Feldenkrais method, Alexander technique, Pilates, Rolfing Structural Integration, and Trager Psychophysical Integration; - Energy therapies: magnet therapy, light therapy, qi gong, Reiki, and healing touch | Interventions used in a continuation or maintenance phase Dietary supplements Standard psychotherapies (e.g., prolonged exposure) and extensions of these therapies (e.g., mindfulness-based cognitive therapy) Relaxation used as a control arm or reported without describing the key components Biofeedback
Comparators | Studies comparing an eligible treatment to a control condition such as usual care (including no treatment), supportive therapy, attention control, sham intervention, or a waitlist Studies comparing an eligible treatment to an empirically based treatment, prolonged exposure, cognitive processing therapy, or antidepressant medication | None
Outcomes | Change in level of depressive or anxiety symptoms (i.e., on self-report and/or clinician-administered measures, including remission rates) or change in quality of life (i.e., functional status and health-related quality of life) Reported at ≥ 6 weeks after treatment initiation | None
Setting | Patients recruited from community or outpatient mental health or general medical settings | None.

Abbreviations: DSM = Diagnostic and Statistical Manual of Mental Disorders, VA = Veterans Affairs