# SEARCH STRATEGIES

Step | Goal | Terms | Result
1 | Anxiety Terms | (generalized[tiab] AND anxiety[tiab] AND disorder[tiab]) OR “generalized anxiety disorder” OR ”generalised anxiety disorder”[tiab] OR “panic disorder”[tiab] OR “panic disorder”[mesh] OR “phobic disorders”[Mesh] OR agoraphobia[Mesh] OR “obsessive-compulsive disorder”[Mesh] OR “stress disorders, traumatic, acute”[mesh] OR “anxiety disorder NOS”[tiab] OR (“Adjustment Disorder”[tiab] AND anxiety[tiab]) OR “adjustment disorders/therapy”[mesh] | 27999
2 | Depression terms | Depressive disorder[Mesh] OR “subsyndromal depression”[tiab] OR “subthreshold depression”[tiab] OR “minor depression”[tiab] | 68923
3 | Interventions | Acupuncture Therapy[Mesh:noexpl] OR Acupuncture Analgesia[Mesh] OR Acupuncture, Ear[Mesh] OR Electroacupuncture[Mesh] OR Acupuncture[Mesh] OR Acupressure[Mesh] OR Auriculotherapy[Mesh] OR acupuncture[All Fields] OR (acupuncture[All Fields] AND therapy[All Fields]) OR (acupuncture therapy[All Fields]) OR acupressure[All Fields] OR auriculotherapy[All Fields] OR Mind-Body Therapies[Mesh:noexpl] OR Breathing Exercises[Mesh] OR Hypnosis[Mesh] OR Imagery (Psychotherapy)[Mesh] OR Meditation[Mesh] OR Mental Healing[Mesh] OR Relaxation Therapy[Mesh] OR Tai Ji[Mesh] OR Therapeutic Touch[Mesh] OR Yoga[Mesh] OR Mind-Body Relations, Metaphysical[Mesh] OR breath[All Fields] OR breath[All Fields:expl] OR Complementary Therapies[Mesh:noexpl] OR Holistic Health[Mesh] OR Medicine, East Asian Traditional[Mesh] OR Reflexotherapy[Mesh] OR Spiritual Therapies[Mesh] OR acoustics[MeSH] OR acoustics[All Fields] OR acoustic[All Fields] OR aromatherapy [MeSH] OR sensory[All Fields] OR aromatherapy[All Fields] OR art[MeSH] OR art[All Fields] OR colour[All Fields] OR color[MeSH] OR color[All Fields] OR dance[All Fields] OR music[MeSH] OR music[All Fields] OR play and playthings[MeSH] OR (play AND playthings[All Fields]) OR play and playthings[All Fields] OR play[All Fields] OR sensory art therapies[MeSH] OR reflexotherapy[All Fields] OR craniosacral[All Fields] OR magnet[All Fields] OR light[MeSH ] OR light[All Fields] OR feldenkrais [Tiab] OR Alexander[Tiab] OR pilates[All Fields] OR trager[All Fields] OR movement therapeutic[All Fields] OR movement therapies[All Fields] OR movement therapy[All Fields] OR healers[All Fields] OR energy[All Fields] OR therapeutic touch[MeSH] OR (therapeutic[All Fields] AND touch[All Fields]) OR therapeutic touch[All Fields] OR reiki[All Fields]) OR ayurvedic[All Fields] | 1689320
3 | Study designs | Cochrane Database Syst Rev [TA] OR search[Title/Abstract] OR meta-analysis[Publication Type] OR MEDLINE[Title/abstract] OR (systematic[Title/Abstract] AND review[Title/Abstract]) OR Systematic[sb] | 271733
4 | Combine results and apply limits | (#1 OR #2) AND #3 AND #4 LIMITS: English and Human and Years 2006-7/1/2011 | 133